# Appendixes

Appendix A Literature Search Strategies

Appendix B Data Collection Forms

Appendix C Previously Published Meta-Analyses

Appendix D Evidence Tables

Appendix E Excluded Studies

Appendix F Adverse Events Analyses