# Acknowledgments

This study was supported by the Agency for Healthcare Research and Quality. The investigators deeply appreciate the considerable support, commitment and contributions of Di Valentine.