# Abbreviations and Acronyms

ACES: Agitation-Calmness Evaluation Scale
ACTeRS: ADD-H Comprehensive Teachers Rating Scale
ADAS: Alzheimer's Disease Assessment Scale
ADDES-S: Attention-Deficit Disorders Evaluation Scale: Secondary-Age Student
ADHD: Attention-deficit hyperactivity disorder
ADHD-SC4: ADHD Symptom Checklist
AHRQ: Agency for Healthcare Research and Quality
ASEBA: Achenbach System for Empirically Based Assessment
ASI-drug: Addiction Severity Index Drug Composite Score
BAI: Beck Anxiety Inventory
BASC-2: Behavior Assessment System for Children-2
BDI: Beck Depression Inventory
BEHAVE-AD: Behavioral Pathology in Alzheimer's Disease Rating Scale
BMI: Body mass index
BPD: Borderline personality disorder
BPRS: Brief Psychiatric Rating Scale
BRMES: Bech-Rafaelson Melancholia Scale
BSI: Brief Symptom Inventory
CAARS: Conners' Adult ADHD Rating Scales
CAPS: Clinician-Administered PTSD Scale
CAS-P: Children's Aggression Scale - Parent Version
CAS-T: Children's Aggression Scale - Teacher Version
CBT: Cognitive behavioral therapy
CCQ: Cocaine Craving Questionnaire
CENTRAL: Cochrane Central Register of Controlled Trials
CER: Comparative Effectiveness Review
CES-D: Center for Epidemiologic Studies Depression Scale
CGI-I: Clinical Global Impression Scale - Improvement subscale
CGI-S: Clinical Global Impression Scale - Severity Subscale
CI: Confidence interval
CIBIC: Clinician's Interview-Based Impression of Change
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMAI: Cohen-Mansfield Agitation Inventory
CSCAADD: Copeland Symptom Checklist for Adult Attention-Deficit Disorders
CVA: Cerebrovascular accident
DARE: Database of Abstracts of Reviews of Effects
DAS-A: Daily Assessment of Symptoms - Anxiety
DIS-Q: Dissociation Questionnaires
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4th. Edition
E-BEHAVE-AD: Empirical Behavioral Pathology in Alzheimer's Disease Rating Scale
ED: Emergency department
EDEQ: Eating Disorders Examination Questionnaire Version
EMBASE: Biomedical and Pharmacological Bibliographic Database
EPC: Evidence-based Practice Center
EPS: Extrapyramidal symptoms
FDA: Food and Drug Administration
FGA: First generation antipsychotics
GAD: Generalized anxiety disorder
GAF: Global Assessment of Functioning Scale
HAM-A: Hamilton Anxiety Rating Scale
HAM-D/HDRS: Hamilton Depression Rating Scale
ISQ: Insomnia Symptom Questionnaire
KQ: Key Question
MADRS: Montgomery-Asberg Depression Rating Scale
MDD: Major depressive disorder
MMSE: Mini Mental Status Exam
MR: Mentally retarded
NC: Not calculated
NNH: Number needed to harm
NPI: Neuropsychiatric Inventory
NPI-NH: Neuropsychiatric Inventory, Nursing Home
OAS-M: Overt Aggression Scale-Modified
OCD: Obsessive-compulsive disorder
PANSS: Positive and Negative Symptom Scale
PCT: Placebo controlled trial
PD: Personality disorders
PDC: Depression Cluster
PRS: Parent's Rating Scale
PTSD: Post-traumatic stress disorder
QEWP-R: Questionnaire on Eating and Weight Patterns- Revised
RCT: Randomized controlled trial
RR: Relative risks
SCHIP: State Children's Health Insurance Program
SCL-90: Symptom Checklist-90
SCL-90-R: Symptom Checklist-90-revised
SDS: Sheehan Disability Scale
SF36: Medical Outcomes Study 36-Item Short-Form Health Survey
SIAB: Structured Interview for Anorexia and Bulimia
SNAP-IV: Swanson, Nolan and Pelham Rating Scale
SPI: Medical Outcomes Study (MOS) Sleep Problem Index
SRC: Scientific Resource Center
SRI: Serotonin reuptake inhibitor
SSRI: Selective serotonin reuptake inhibitor
STAXI: State-Trait Anger Expression Inventory
TEP: Technical expert panel
TMR: Therapist Monitoring Record
TSSR: Tic Symptom Self Report
VA: U.S. Department of Veterans Affairs
WURS: Wender Utah Rating Scale
Y-BOCS: Yale-Brown Obsessive-Compulsive Scale
ZAN-BPD: Zanarini Rating Scale for Borderline Personality Disorder