# References and Included Studies

1 Smith JC Jr, Feldman TE, Hirshfeld JW Jr, et al. ACC/AHA/SCAI 2005 guideline update for percutaneous coronary intervention: a report of the American College of Cardiology/American Heart Assoc Task Force on Practice Guidelines (ACC/AHA/SCAI Writing Committee to Update the 2001 Guidelines for Percutaneous Coronary Intervention. J Am Coll Cardiol. 2005;47:1-121. [pmid: 16386657].
2 Gumina RJ. New trials and therapies for acute myocardial infarction. Med Clin North Am. 2007;91:729-49. [pmid: 17640545].
3 Silber S, Albertsson P, Aviles FF, et al. Guidelines for percutaneous coronary intervention. Eur Heart J. 2005;26:804-47. [pmid: 15769784].
4 Silber S, Albertsson P, Aviles FF, et al. Guidelines for percutaneous coronary intervention. J Am Coll Cardiol. 2003;42:1739-46. [pmid: 14642681].
5 Silber S, Albertsson P, Aviles FF, et al. Guidelines for percutaneous coronary intervention. N Engl J Med. 2002;346:957-66. [pmid: 11919304].
6 Mehta RH, Harjai KJ, Cox D, et al. Clinical and angiographic correlates and outcomes of suboptimal coronary flow inpatients with acute myocardial infarction undergoing primary percutaneous coronary intervention. J Am Coll Cardiol. 2003;42:1739. [pmid: 14642681].
7 Chesebro JH, Knatterud G, Roberts R, et al. Thrombolysis in Myocardial Infarction (TIMI) Trial, Phase I: A comparison between intravenous tissue plasminogen activator and intravenous streptokinase. Clinical findings through hospital discharge. Circulation. 1987;76:142-54. [pmid: 3109764].
8 van 't Hoff AW, Liem A, Suryapranata H, et al. Angiographic assessment of myocardial reperfusion in patients treated with primary angioplasty for acute myocardial infarction: myocardial blush grade. Zwolle Myocardial Infarction Study Group. Circulation. 1998;97:2302-6. [pmid: 9639373].
9 Mamas MA, Fraser D, Fath-Ordoubadi F. The role of thrombectomy and distal protection devices during percutaneous coronary interventions. Eurointervention. 2008;4:115-23. [pmid: 19112788].
10 FDA device website. Available at: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm. Sept 15, 2010.
11 Migliorini A, Stabile A, Rodriguez AE, et al. Comparison of AngioJet Rheolytic Thrombectomy Before Direct Infarct Artery Stenting With Direct Stenting Alone in Patients With Acute Myocardial Infarction The JETSTENT Trial. J Am Coll Cardiol. 2010. [Epub ahead of print]. [pmid: 20691553].
12 Liistro F, Grotti S, Angioli P, et al. Impact of thrombus aspiration on myocardial tissue reperfusion and left ventricular functional recovery and remodeling after primary angioplasty. Circ Cardiovasc Interv. 2009;2:376-83. [pmid: 20031746].
13 Lipiecki J, Monzy S, Durel N, et al. Effect of thrombus aspiration on infarct size and left ventricular function in high-risk patients with acute myocardial infarction treated by percutaneous coronary intervention. Results of a prospective controlled pilot study. Am Heart J. 2009;157:583.e1-583.e7. [pmid: 19249433].
14 Sardella G, Mancone M, Bucciarelli-Ducci C, et al. Thrombus aspiration during primary percutaneous coronary intervention improves myocardial reperfusion and reduces infarct size: the EXPIRA (thrombectomy with export catheter in infarct-related artery during primary percutaneous coronary intervention) prospective, randomized trial. J Am Coll Cardiol. 2009;53:309-15. [pmid: 19161878].
15 Chevalier B, Gilard M, Lang I, et al. Systematic primary aspiration in acute myocardial percutaneous intervention: a multicentre randomised controlled trial of the export aspiration catheter. EuroIntervention. 2008;4:222-8. [pmid: 19110787].
16 Ikari Y, Sakurada M, Kozuma K, et al. Upfront thrombus aspiration in primary coronary intervention for patients with ST-segment elevation acute myocardial infarction: report of the VAMPIRE (VAcuuM asPIration thrombus REmoval) trial. JACC Cardiovasc Interv. 2008;1:424-31. [pmid: 19463340].
17 Tahk SJ, Choi BJ, Choi SY, et al. Distal protection device protects microvascular integrity during primary percutaneous intervention in acute myocardial infarction: a prospective, randomized, multicenter trial. Int J Cardiol. 2008;123:162-8. [pmid: 17490759].
18 Haeck JD, Koch KT, Bilodeau L, et al. Randomized comparison of primary percutaneous coronary intervention with combined proximal embolic protection and thrombus aspiration versus primary percutaneous coronary intervention alone in ST-segment elevation myocardial infarction: the PREPARE (PRoximal Embolic Protection in Acute myocardial infarction and Resolution of ST-Elevation) study. JACC Cardiovasc Interv. 2009;2:934-43. [pmid: 19850252].
19 Dudek D. Polish-Italian-Hungarian randomized thrombectomy trial [slide presentation]. Apr 23, 2010.
20 Moura R, Barreto F, Costa M, et al. Improvement of Reperfusion Rates With Thrombectomy Catheter in Acute Myocardial Infarction. J Am Coll Cardiol. 2009;53:A329.
21 Ciszewski M, Pregowski J, Teresinska A, et al. Aspiration Coronary Thrombectomy for Acute Myocardial Infarction Improves Myocardial Salvage Index. Single Center Randomized Study. Circulation. 2008;118:S764.
22 Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/guides-cmece-and-other-resources-for-clinicians/cmece-activities/#ahrq. July 27, 2010.
23 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
24 Egger M, Smith GD, Schneider M, et al. Bias in Meta-Analysis Detected by a Simple, Graphical Test. BMJ. 1997;315:629-34. [pmid: 9310563].
25 Altman DG, Bland JM. Interaction revisited: the difference between two estimates. BMJ. 2003;326:219. [pmid: 12543843].
26 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. 2006;59:1040-8. [pmid: 16980143].
27 Antoniucci D, Valenti R, Migliorini A, et al. Comparison of rheolytic thrombectomy before direct infarct artery stenting versus direct stenting alone in patients undergoing percutaneous coronary intervention for acute myocardial infarction. Am J Cardiol. 2004;93:1033-5. [pmid: 15081450].
28 Parodi G, Valenti R, Migliorini A, et al. A randomized trial comparing rheolytic thrombectomy before infarct artery stenting with stenting alone in patients undergoing percutaneous coronary intervention for acute myocardial infarction. J Am Coll Cardiol. 2004;43:286A.
29 Lefevre T, Garcia E, Reimers B, et al. X-sizer for thrombectomy in acute myocardial infarction improves ST-segment resolution: results of the X-sizer in AMI for negligible embolization and optimal ST resolution (X AMINE ST) trial. J Am Coll Cardiol. 2005;46:246-52. [pmid: 16022950].
30 Lelfevre T, Ludwig J, Garcia E, et al. Randomized study to evaluate the effect on ST-segment resolution using the X-Sizer XT catheter system in acute myocardial infarction patients (X-AMINE ST study). Am J Cardiol. 2004;94:154E-5E.
31 Lefevre T, Ludwig J, Garcia E. X-SIZER in acute myocardial infarction. Results of a European Randomized Trial (XAMINE ST). Am J Cardiol. 2003;92:36L.
32 Lefevre T. Preliminary results of a randomized trial using X-SIZER in acute myocardial infarction for negligible embolization and optimal ST-segment resolution (XAMINE ST). Am J Cardiol. 2002;90:TCT266.
33 Lefevre T, Ludwig J, Nonnekens R, et al. Preliminary results of a randomized trial using X-SIZER in acute myocardial infarction for negligible embolization and optimal ST segment resolution (Xamine ST). Circulation. 2002;106:1663.
34 Garcia E. X-SIZER in AMI patients for negligible embolization and optimal ST resolution [slide presentation]. Apr 23, 2010.
35 Morice MC. Insights from completed studies-potential of futility? X-AMINE ST (thrombectomy): reperfusion and clinical results [slide presentation]. Apr 23, 2010.
36 Morice MC. Filters in AMI may work where balloon occlusion/aspiration systems don't: DIPLOMAT [slide presentation]. Apr 23, 2010.
37 Morice MC. Thrombectomy in AMI revisited: X AMINE ST update, and a trial of simple aspiration [slide presentation]. Apr 23, 2010.
38 Lefevre T, Ludwig J. X-Sizer in AMI patients for negligible embolization and optimal ST resolution [slide presentation]. Apr 23, 2010.
39 Lefevre T, Ludwig J. Results of trial data: X-Sizer in acute myocardial infarction to examine negligible embolization and ST-segment elevation resolution [slide presentation]. Apr 23, 2010.
40 Ali A, Cox D, Dib N, et al. Rheolytic thrombectomy with percutaneous coronary intervention for infarct size reduction in acute myocardial infarction: 30-day results from a multicenter randomized study. J Am Coll Cardiol. 2006;48:244-52. [pmid: 16843170].
41 Ali A. Angio-Jet rheolytic thrombectomy in patients undergoing primary angioplasty for acute myocardial infarction [slide presentation]. Apr 23, 2010.
42 Ali A. Is thrombectomy of benefit in any patients with STEMI? Long term and subset data from AiMI [slide presentation]. Apr 23, 2010.
43 Sianos G. Rheolytic thrombectomy after the failed AiMI trial: role in large thrombus burden and stent thrombosis [slide presentation]. Apr 23, 2010.
44 Napodano M, Pasquetto G, Sacca S, et al. Intracoronary thrombectomy improves myocardial reperfusion in patients undergoing direct angioplasty for acute myocardial infarction. J Am Coll Cardiol. 2003;42:1395-402. [pmid: 14563581].
45 Reimers B, Favero L, Napodano M. Defending the microcirculation: distal protection and thrombectomy devices in the coronary circulation [slide presentation]. Apr 23, 2010.
46 Antoniucci D, on behalf of the JETSTENT Investigators. Comparison of Angiojet rheolytic thrombectomy before direct infarct related artery stenting in patients with acute myocardial infarction : the JETSTENT trial [slide presentation]. Apr 23, 2010.
47 Antoniucci D, on behalf of the JETSTENT Investigators. Comparison of Angiojet rheolytic thrombectomy before direct infarct related artery stenting in patients with acute myocardial infarction : the JETSTENT trial [slide presentation]. Apr 23, 2010.
48 Liistro F. Impact of thrombus aspiration on myocardial tissue reperfusion and left ventricular functional recovery and remodeling after primary angioplasty [slide presentation]. Apr 23, 2010.
49 Sardella G, Mancone M, Canali E, et al. Impact of thrombectomy with Export catheter in infarct related artery during primary PCI on procedural outcome in patients with acute myocardial infarction (EXPIRA trial). 24 month clinical outcomes [slide presentation]. Apr 23, 2010.
50 Sardella G, Mancone M, Di Roma A, et al. Impact of thrombectomy with Export catheter in infarct related artery during primary PCI on procedural outcomes in patients with acute myocardial infarction (EXPIRA trial) [slide presentation]. Apr 23, 2010.
51 Chevalier B, Parikh K, Boschat J, et al. EXPORT Study first report [slide presentation]. Apr 23, 2010.
52 Ciszewski M, Pregowski J, Teresinska A, et al. Randomized study on coronary thrombectomy for acute myocardial infarction with ST segment elevation. Eur Heart J. 2006;27(suppl):771.
53 Ciszewski M, Pregowski J, Debski A, et al. Randomized study on coronary thrombectomy for acute myocardial infarction with ST segment elevation. Am J Cardiol. 2006;98:60M-1M. [pmid: 16784921].
54 Kozuma K, Ikari Y, Fujii K, et al. Three-year Clinical Follow-up of the Vampire Study in St Elevation Acute Myocardial Infarction (STEMI) Patients With Thrombus Aspiration Prior to Coronary Intervention. Circulation. 2009;120:S985.
55 Kozuma K, Ikari Y, Sakurada M, et al. Long-term clinical follow-up in ST elevation acute myocardial infarction (STEMI) patients with thrombus aspiration prior to coronary intervention, 2-year results of the Vampire study. Circulation. 2007;116:1784. [pmid: 17909107].
56 Kozuma K, Suzuki N, Tanabe K, et al. The impact of the thrombus aspiration on the final TIMI flow in patients with ST-elevation myocardial infarction (STEMI). J Am Coll Cardiol. 2006;47:185A-6A.
57 Ikari Y, Kawano S, Sakurada M, et al. Thrombus aspiration prior to coronary intervention improves myocardial microcirculation in patients with ST elevation acute myocardial infarction, the VAMPIRE study. Circulation. 2005;112:3091.
58 Isshiki T, Ikari Y, Sakurada M, et al. Thrombus aspiration prior to coronary intervention improves myocardial microcirculation in patients with ST elevation acute myocardial infarction, the VAMPIRE study. Am J Cardiol. 2006;98:60M. [pmid: 16784921].
59 Isshiki T, Kozuma K, Sakurada M, et al. Eur Heart J. 2006;27:1022.
60 Kyono H, Kozuma K, Ikari Y, et al. Thrombectomy Improves Angiographic Outcome in ST-Segment Elevation Myocardial Infarction Cases without Visible Thrombus: Subanalysis from the VAMPIRE trial. J Am Coll Cardiol. 2009;53:A64.
61 Isshiki T. VAMPIRE: Vacuum aspiration thrombus removal [slide presentation]. Apr 23, 2010.
62 Svilaas T, Vlaar PJ, van der Horst IC, et al. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med. 2008;358:557-67. [pmid: 18256391].
63 Fokkema ML, van der Vleuten PA, Vlaar PJ, et al. Incidence, predictors, and outcome of reinfarction and stent thrombosis within one year after primary percutaneous coronary intervention for ST-elevation myocardial infarction. Catheter Cardiovasc Interv. 2009;73:627-34. [pmid: 19309712].
64 Vlaar PJ, Svilaas T, van der Horst IC, et al. Cardiac death and reinfarction after 1 year in the Thrombus Aspiration during Percutaneous coronary intervention in Acute myocardial infarction Study (TAPAS): a 1-year follow-up study. Lancet. 2008;371:1915-20. [pmid: 18539223].
65 Svilaas T, van der Horst IC, Zijlstra F. Thrombus Aspiration during Percutaneous coronary intervention in Acute myocardial infarction Study (TAPAS)--study design. Am Heart J. 2006;151:597.e1-597.e7. [pmid: 16504620].
66 van der Vleuten PA, Vogelzang M, Svilaas T, et al. Predictive value of Q waves on the 12-lead electrocardiogram after reperfusion therapy for ST elevation myocardial infarction. J Electrocardiol. 2009;42:310-8. [pmid: 19362318].
67 de Smet BJ. Thrombus aspiration during percutaneous coronary intervention in acute myocardial infarction study (TAPAS): mortality and MACE at 1 year followup [slide presentation]. Apr 23, 2010.
68 Chao CL, Hung CS, Lin YH, et al. Time-dependent benefit of initial thrombosuction on myocardial reperfusion in primary percutaneous coronary intervention. Int J Clin Pract. 2008;62:555-61. [pmid: 18067561].
69 De Luca L, Sardella G, Davidson CJ, et al. Impact of intracoronary aspiration thrombectomy during primary angioplasty on left ventricular remodelling in patients with anterior ST elevation myocardial infarction. Heart. 2006;92:951-7. [pmid: 16251226].
70 De Luca L, Sardella G, Di Roma A, et al. Effects of thrombectomy on long-term mortality after primary percutaneous coronary intervention. Am J Cardiol. 2004;94:155E.
71 Kaltoft A, Bottcher M, Nielsen SS, et al. Routine thrombectomy in percutaneous coronary intervention for acute ST-segment-elevation myocardial infarction: a randomized, controlled trial. Circulation. 2006;114:40-7. [pmid: 16801464].
72 Andersen NH, Karlsen FM, Gerdes JC, et al. No beneficial effects of coronary thrombectomy on left ventricular systolic and diastolic function in patients with acute S-T elevation myocardial infarction: a randomized clinical trial. J Am Soc Echocardiogr. 2007;20:724-30. [pmid: 17543743].
73 Kaltoft A, Bottcher M, Nielsen SS, et al. Thrombectomy as an adjunct to percutaneous coronry intervention in ST-segment elevation myocardial infarction [slide presentation]. Apr 23, 2010.
74 Silva-Orrego P, Colombo P, Bigi R, et al. Thrombus aspiration before primary angioplasty improves myocardial reperfusion in acute myocardial infarction: the DEAR-MI (Dethrombosis to Enhance Acute Reperfusion in Myocardial Infarction) study. J Am Coll Cardiol. 2006;48:1552-9. [pmid: 17045887].
75 Silva-Orrego P, Bigi R, Colombo P, et al. Direct stenting after thrombus removal before primary angioplasty in acute myocardial infarction. J Intervent Cardiol. 2008;21:300-6. [pmid: 18754965].
76 Colombo P, Silva B, Bigi R, et al. Thrombus aspiration improves coronary flow and myocardial reperfusion in acute myocardial infarction: Final results of the DEAR MI (dethrombosis to enhance acute reperfusion in myocardial infarction) study. Am J Cardiol. 2005;96:74H-5H. [pmid: 15979438].
77 Colombo P, Silva P, Delgado A, et al. Thrombus aspiration with the pronto extraction catheter before standard percutaneous coronary intervention improves myocardial reperfusion: Preliminary results of a prospective randomized study. Am J Cardiol. 2004;94:12E-3E.
78 Colombo P, Orrego PSOS, Bigi RB, et al. Thrombus aspiration improves myocardial reperfusion in acute myocardial infarction: the DEAR-MI (Dethrombosis to Enhance Acute Reperfusion in Myocardial Infarction) study. Eur Heart J. 2006;27:771-2.
79 Oreglia JA, Silva-Orrego P, Colombo P, et al. Impact of thrombus aspiration in acute myocardial infarction on procedural aspects of primary percutancous intervention. Am J Cardiol. 2006;98:25M.
80 SilvaOrrego P, Colombo P, Delgado A, et al. DEAR-MI: A randomized study comparing standard primary PCI versus PCI with thrombus aspiration in acute myocardial infarction [slide presentation]. Apr 23, 2010.
81 Oreglia J, SilvaOrrego P, Colombo P, et al. Impact of thrombus aspiration in acute myocardial infarction on procedural aspects of primary percutaneous intervention [slide presentation]. Apr 23, 2010.
82 SilvaOrrego P. DEAR-MI: Dethrombosis to enhance acute reperfusion in myocardial infarction [slide presentation]. Apr 23, 2010.
83 Burzotta F, Trani C, Romagnoli E, et al. Manual thrombus-aspiration improves myocardial reperfusion: the randomized evaluation of the effect of mechanical reduction of distal embolization by thrombus-aspiration in primary and rescue angioplasty (REMEDIA) trial. J Am Coll Cardiol. 2005;46:371-6. [pmid: 16022970].
84 Galiuto L, Garramone B, Burzotta F, et al. Thrombus aspiration reduces microvascular obstruction after primary coronary intervention: a myocardial contrast echocardiography substudy of the REMEDIA Trial. J Am Coll Cardiol. 2006;48:1355-60. [pmid: 17010794].
85 Noel B, morice MC, Lefevre T. Thromboaspiration in acute ST elevation MI improves myocardial infarction. Circulation. 2005;112(Suppl. II):519.
86 Lee SY, Joon HD, June N, et al. Export aspiration catheter thrombo-suction before actual primary PCI in AMI: TSUNAMI study. Circulation. 2006;114:597. [pmid: 16894049].
87 Dudek D, Mielecki W, Chyrchel M, et al. Percutaneous thrombectomy before stenting in acute myocardial infarction-randomized study. Eur Heart J. 2004;25:421.
88 Dudek D, Mielecki W, Legutko J, et al. Percutaneous thrombectomy with the RESCUE system in acute myocardial infarction. Kardiol Pol. 2004;61:523-33. [pmid: 15815753].
89 Kelbaek H, Terkelsen CJ, Helqvist S, et al. Randomized comparison of distal protection versus conventional treatment in primary percutaneous coronary intervention: the drug elution and distal protection in ST-elevation myocardial infarction (DEDICATION) trial. J Am Coll Cardiol. 2008;51:899-905. [pmid: 18308157].
90 Kaltoft A, Nielsen SS, Terkelsen CJ, et al. Scintigraphic evaluation of routine filterwire distal protection in percutaneous coronary intervention for acute ST-segment elevation myocardial infarction: a randomized controlled trial. J Nucl Cardiol. 2009;16:784-91. [pmid: 19521742].
91 Kofoed KF, Kelbaek H, Thuesen L, et al. Clinical Outcome and Left Ventricular Contractile Function After Distal Protection In Primary Percutaneous Coronary Intervention The Drug Elution and Distal Protection in ST-Elevation Myocardial Infarction (DEDICATION) Trial. Circulation. 2008;118:S763.
92 Thuesen L, Kelbaek H, Lassen JF, et al. Randomized comparison of the effect of distal protection and drug eluting stent versus bare metal stent implantation during percutaneous coronary intervention for TS-segment elevation myocardial infarction [slide presentation]. Apr 23, 2010.
93 Cura F, Escudero AG, Grinfeld L, et al. J Am Coll Cardiol. 2006;47:186A.
94 Cura F, Garcia E, Trivi M, et al. Protection of distal embolization in high-risk patients with acute ST-segment elevation myocardial infarction randomized controlled trial 6 month results [slide presentation]. Apr 23, 2010.
95 Cura FA, Escudero AG, Berrocal D, et al. Protection of Distal Embolization in High-Risk Patients with Acute ST-Segment Elevation Myocardial Infarction (PREMIAR). Am J Cardiol. 2007;99:357-63. [pmid: 17261398].
96 Cura FA, Padilla LT, Damonte A, et al. Protection of distal embolization in high-risk patients with acute ST-segment elevation myocardial infarction (PREMIAR) randomized controlled trial: 6-month results. Am J Cardiol. 2006;98:38M-9M.
97 Guetta V. The UPFLOW MI trial [slide presentation]. Apr 23, 2010.
98 Guetta V, Mosseri M, Shechter M, et al. Safety and efficacy of the FilterWire EZ in acute ST-segment elevation myocardial infarction. Am J Cardiol. 2007;99:911-5. [pmid: 17398182].
99 Lefevre T, Guyon P, Reimers B, et al. Distal protection in acute myocardial infarction: final results of the randomized DIPLOMAT study. Eur Heart J. 2004;25:420.
100 Lefevre T, Guyon P, Reimers B, et al. Evaluation of a distal protection filter device in patients with acute myocardial infarction: The DIPLOMAT study. Am J Cardiol. 2003;92:37L-8L.
101 Lefevre T, Guyon P, Reimers B, et al. Evaluation of a distal protection filter device in patients with acute myocardial infarction: Final results of the DIPLOMAT study. J Am Coll Cardiol. 2004;43:72A.
102 Tahk SJ, Chae IH, Choi SY, et al. Fate of unprotected side branches due to distal embolization during stent implantation for acute coronary syndromes using distal protection procedure. Circulation. 2004;110:3510.
103 Hahn JY, Gwon HC, Choe YH, et al. Effects of balloon-based distal protection during primary percutaneous coronary intervention on early and late infarct size and left ventricular remodeling: a pilot study using serial contrast-enhanced magnetic resonance imaging. Am Heart J. 2007;153:665.e1-665.e8. [pmid: 17383309].
104 Hahn JY, Gwon HC, Choe YH, et al. Effects of balloon-based distal protection during primary percutaneous coronary intervention on early and late infarct size and left ventricular remodeling: Serial contrast-enhanced magnetic resonance imaging analysis. Am J Cardiol. 2007;99:42F. [pmid: 17196459].
105 Rhee I, Gwon HC, Choe YH, et al. Distal protection reduces infaret size after primary angioplasty in acute myocardial infarction: Magnetic resonance imaging study. Am J Cardiol. 2005;95:10A.
106 Rhee I, Gwon HC, Choi YH, et al. Distal protection reduces infarct size after primary angioplasty in acute myocardial infarction: Magnetic resonance imaging. Am J Cardiol. 2004;94:36E.
107 Matsuo A, Inoue N, Suzuki K, et al. Limitations of using a GuardWire temporary occlusion and aspiration system in patients with acute myocardial infarction: multicenter investigation of coronary artery protection with a distal occlusion device in acute myocardial infarction (MICADO). J Invasive Cardiol. 2007;19:132-8. [pmid: 17341781].
108 Fujita N, Suwa S, Koyama S, et al. The efficacy of distal embolic protection device during an acute myocardial infarction: Early and long-term results. Am J Cardiol. 2004;94:34E.
109 Ito Y, Muramatsu T, Fuijita N, et al. Effectiveness of the PercuSurge distal embolic protection device in treatment of high-risk cases of acute myocardial infarction by intravenous ultrasound analyses: Data from the Japanese ASPARAGUS trial. Am J Cardiol. 2005;95:1A. [pmid: 15619385].
110 Muramatsu T. The Japanese ASPARGUS trial [slide presentation]. Apr 23, 2010.
111 Zhou BQ, Tahk SJ. Effect of a distal protection device on epicardial blood flow and myocardial perfusion in primary percutaneous coronary intervention. J Zhejiang Univ Sci B. 2007;8:575-9. [pmid: 17657860].
112 Stone GW, Webb J, Cox DA, et al. Distal microcirculatory protection during percutaneous coronary intervention in acute ST-segment elevation myocardial infarction: a randomized controlled trial. JAMA. 2005;293:1063-72. [pmid: 15741528].
113 Marso SP, Miller T, Rutherford BD, et al. Comparison of myocardial reperfusion in patients undergoing percutaneous coronary intervention in ST-segment elevation acute myocardial infarction with versus without diabetes mellitus (from the EMERALD Trial). Am J Cardiol. 2007;100:206-10. [pmid: 17631071].
114 Brodie BR, Webb J, Cox DA, et al. Impact of time to treatment on myocardial reperfusion and infarct size with primary percutaneous coronary intervention for acute myocardial infarction (from the EMERALD Trial). Am J Cardiol. 2007;99:1680-6. [pmid: 17560875].
115 Dangas G, Stone GW, Weinberg MD, et al. Contemporary outcomes of rescue percutaneous coronary intervention for acute myocardial infarction: comparison with primary angioplasty and the role of distal protection devices (EMERALD trial). Am Heart J. 2008;155:1090-6. [pmid: 18513524].
116 Stone GW, Webb J, Cox DA, et al. Primary angioplasty in acute myocardial infarction with distal protection of the microcirculation: Principal results from the prospective, randomized EMERALD trial. J Am Coll Cardiol. 2004;43:285A-6A.
117 Stone GW, Cox DA, Brodie BR, et al. Primary angioplasty in acute myocardial infarction with distal protection of the microcirculation: Results from the roll-in phase of the EMERALD trial. Circulation. 2003;108:1913.
118 Stone GW. The EMERALD trial Guardwire distal protection in AMI 6 month results and analysis [slide presentation]. Apr 23, 2010.
119 Okamura A, Ito H, Iwakura K, et al. Detection of embolic particles with the Doppler guide wire during coronary intervention in patients with acute myocardial infarction: efficacy of distal protection device. J Am Coll Cardiol. 2005;45:212-5. [pmid: 15653017].
120 Haeck JD, Koch KT, Bilodeau L, et al. Randomized Comparison of Primary Percutaneous Coronary Intervention With Combined Proximal Embolic Protection and Thrombus Aspiration and Primary Percutaneous Coronary Intervention Alone in ST-segment Elevation Myocardial Infarction. J Am Coll Cardiol. 2009;53:A28.
121 Koch KT, Haeck JD, Tijssen JG, et al. A prospective randomized trial of proximal microcirculatory protection in patients with acute myocardial infarction undergoing primary PCI [slide presentation]. Apr 23, 2010.
122 Koch K, Haeck J, Bilodeau L, et al. Randomized Comparison of Primary Percutaneous Coronary Intervention with Combined Proximal Embolic Protection and Thrombus Aspiration versus Primary Percutaneous Coronary Intervention Alone in ST-segment Elevation Myocardial Infarction. Am J Cardiol. 2009;103:AS46.
123 Parikh KH, Shah HA, Chag MC, et al. Efficacy of PercuSurge in acute myocardial infarction patients undergoing revascularization with a special emphasis on procedural time. Indian Heart J. 2008;60:101-19. [pmid: 19218717].
124 Parikh KH, Shah HA, Shah JN, et al. Study of percusurge in acute myocardial infarction patients undergoing revascularization with special emphasis on procedural time. [abstract]. Indian Heart J. 2006;58. Abstract-119.
125 Parikh KH, Shah HD, Chag MC, et al. Revascularization in acute myocardial infarction using Percusurge in distal protection acronym: RAPID. World Heart Journal. 2008;1:35-47.
126 Gick M, Jander N, Bestehorn HP, et al. Randomized evaluation of the effects of filter-based distal protection on myocardial perfusion and infarct size after primary percutaneous catheter intervention in myocardial infarction with and without ST-segment elevation. Circulation. 2005;112:1462-9. [pmid: 16129793].
127 Sardella G, De Luca L, Mancone M, et al. Impact of thromboaspiration device during primary angioplasty on left ventricular remodeling in patients with acute anterior myocardial infarction. Circulation. 2005;112(Suppl. II):519.
128 Kunii H, Kijima M, Araki T, et al. Lack of efficacy of intracoronary thrombus aspiration before coronary stenting in patients with acute myocardial infarction: A multicenter randomized trial. J Am Coll Cardiol. 2004;43:245A-6A.
129 Kunii H, Kyoritsu I, Tamaki K, et al. Intracoronary thrombus aspiration before coronary stenting in patients with acute myocardial infarction: A multicenter randomized trial. Circulation. 2003;108:1911.
130 Nanasato M, Hirayama H, Muramatsu T, et al. Impact of angioplasty with distal protection device on myocardial reperfusion. J Am Coll Cardiol. 2004;43(Suppl. 1):246A.
131 Matsushita M, Muramatsu T, Tsukahara R, et al. Effectiveness of percutaneous coronary intervention using distal protection for acute myocardial infarction in reducing microvascular obstruction. Am J Cardiol. 2003;92:191L.
132 Matsushita M, Muramatsu T, Tsukahara R, et al. Effectiveness of PCI using distal protection for AMI in reducing microvascular obstruction. Circulation. 2003;108:2913.
133 Muramatsu T, Kozuma K, Tsukahara R, et al. Comparison of myocardial perfusion by distal protection before and after primary stenting for acute myocardial infarction: angiographic and clinical results of a randomized controlled trial. Catheter Cardiovasc Interv. 2007;70:677-82. [pmid: 17621653].
134 Gick M, Jander N, Bestehorn H, et al. Randomised study on the effectiveness of a filter device for distal protection during direct percutaneous catheter intervention for acute myocardial infarction. PROMISE Study-6 month follow-up. Eur Heart J. 2005;26:P2216.
135 Duan YY, Zhang HB, Liu LW, et al. Effects of distal protection on left ventricular function in acute anterior myocardial infarction: a Doppler echocardiographic study. Int J Cardiovasc Imaging. 2010;26:125-33. [pmid: 19802729].
136 Pan W, Liu HW, Wang LF, et al. Effect of percutaneous thrombectomy on echocardiographic measures of myocardial microcirculation in elderly patients with acute myocardial infarction. Coron Artery Dis. 2010;21:121-5. [pmid: 20134319].
137 Ito N, Nanto S, Doi Y, et al. Distal protection during primary coronary intervention can preserve the index of microcirculatory resistance in patients with acute anterior ST-segment elevation myocardial infarction. Circ J. 2010;75:94-8. [pmid: 21116072].
138 Dudek D, Mielecki W, Burzotta F, et al. Thrombus aspiration followed by direct stenting: a novel strategy of primary percutaneous coronary intervention in ST-segment elevation myocardial infarction. Results of the Polish-Italian-Hungarian RAndomized ThrombEctomy Trial (PIHRATE Trial). Am Heart J. 2010;160:966-72. [pmid: 21095287].
139 Sardella G, Mancone M, Canali E, et al. Impact of thrombectomy with EXPort Catheter in Infarct-Related Artery during Primary Percutaneous Coronary Intervention (EXPIRA Trial) on cardiac death. Am J Cardiol. 2010;106:624-9. [pmid: 20723635].
140 Kaltoft A, Kelbaek H, Klovgaard L, et al. Increased rate of stent thrombosis and target lesion revascularization after filter protection in primary percutaneous coronary intervention for ST-segment elevation myocardial infarction: 15-month follow-up of the DEDICATION (Drug Elution and Distal Protection in ST Elevation Myocardial Infarction) trial. J Am Coll Cardiol. 2010;55:867-71. [pmid: 20185036].
141 Haeck JD, Kuijt WJ, Koch KT, et al. Infarct size and left ventricular function in the PRoximal Embolic Protection in Acute myocardial infarction and Resolution of ST-segment Elevation (PREPARE) trial: ancillary cardiovascular magnetic resonance study. Heart. 2010;96:190-5. [pmid: 19858136].
142 Kim JH, Sim DS, Cho MC, et al. Clinical benefits of thrombus aspiration during primary percutaneous coronary intervention for acute ST-Elevation Myocardial Infarction. Am J Cardio. 2010;105:31B.
143 De Vita M, Burzotta F, Porto I, et al. Thrombus aspiration in ST elevation myocardial infarction: comparative efficacy in patients treated early and late after onset of symptoms. Heart. 2010;96:1287-90. [pmid: 20659947].
144 Beaudoin J, Dery JP, Lachance P, et al. Impact of thrombus aspiration on angiographic and clinical outcomes in patients with ST-elevation myocardial infarction. Cardiovasc Revasc Med. 2010;11:218-22. [pmid: 20934652].
145 Chinnaiyan KM, Grines CL, O'Neill WW, et al. Safety of AngioJet thrombectomy in acute ST-segment elevation myocardial infarction: a large, single-center experience. J Invasive Cardiol. 2006;18:1721-21C. [pmid: 16883027].
146 Cohen R, Domniez T, Foucher R, et al. Intracoronary thrombectomy with the export aspiration catheter before angioplasty in patients with ST-segment elevation myocardial infarction. J Interv Cardiol. 2007;20:136-42. [pmid: 17391222].
147 Ko J, Jeong MH, Ahn YK, et al. Distal Protection Device in Primary Percutaneous Coronary Intervention for Fresh Acute Myocardial Infarction: Data From Kamir (Korean Acute Myocardial Infarction Registry). Circulation. 2009;120:S925-6.
148 Mehran R, Brodie B, Cox DA, et al. The Harmonizing Outcomes with RevasculariZatiON and Stents in Acute Myocardial Infarction (HORIZONS-AMI) Trial: study design and rationale. Am Heart J. 2008;156:44-56. [pmid: 18585496].
149 Nakatani D, Sato H, Sakata Y, et al. Effect of intracoronary thrombectomy on 30-day mortality in patients with acute myocardial infarction. Am J Cardiol. 2007;100:1212-7. [pmid: 17920359].
150 Nakatani D, Sato H, Sakata Y, et al. Clinical impact of intracoronary thrombectomy on 30-day mortality in patients with acute myocardial infarction who underwent percutaneous coronary intervention. Circulation. 2006;114:740.
151 Nilsen DW, Wu R, Lansky AJ, et al. Impact of Thrombus Aspiration in Patients With STEMI Undergoing Primary PCI: Analysis From the HORIZONS-AMI Trial. Circulation. 2009;120:S986.
152 Nilsen DWT, Wu R, Nordrehaug JE, et al. Impact of Thrombus Aspiration during Primary Percutaneous Coronary Intervention in Acute Myocardial Infarction: Analysis from the HORIZONS-AMI Trial. Am J Cardiol. 2009;104:3D-4D.
153 Simonton CA 3rd, Brodie BR, Wilson H, et al. AngioJet experience from the multi-center STENT Registry. J Invasive Cardiol. 2006;18:22-3. [pmid: 16883028].
154 Kramer MC, van der Wal AC, Koch KT, et al. Presence of older thrombus is an independent predictor of long-term mortality in patients with ST-elevation myocardial infarction treated with thrombus aspiration during primary percutaneous coronary intervention. Circulation. 2008;118:1810-6. [pmid: 18852369].
155 Webster MW. Vascular protection in high risk non-ST-segment elevation acute coronary syndromes [slide presentation]. Apr 23, 2010.
156 Dudek D, Bartus S, Zmudka K, et al. Safety and efficacy of ANGIOGUARD protection device for the prevention of distal embolization during PCI in patients with unstable angina. Przegl Lek. 2003;60:499-503. [pmid: 14974339].
157 Bartus S, Dudek D, Legutko J, et al. Safety and efficacy of Angioguard protection device for prevention of distal embolization during percutaneous coronary intervention in patients with unstable angina. Eur Heart J. 2002;23:552.
158 Sardella G, Mancone M, Nguyen BL, et al. The effect of thrombectomy on myocardial blush in primary angioplasty: the Randomized Evaluation of Thrombus Aspiration by two thrombectomy devices in acute Myocardial Infarction (RETAMI) trial. Catheter Cardiovasc Interv. 2008;71:84-91. [pmid: 17985382].
159 Sardella G, Mancone M, Colantonio R, et al. Randomized evaluation of the effect of thrombus aspiration by two different thrombectomy devices on myocardial blush during primary PCI. J Am Coll Cardiol. 2007;49:30B.
160 Yan HB, Wang J, Li N, et al. Diver CE versus Guardwire Plus for thrombectomy in patients with inferior myocardial infarction: a trial of aspiration of thrombus during primary angioplasty for inferior myocardial infarction. Chin Med J. 2007;120:557-61. [pmid: 17442202].
161 Li N, Yan HB, Zhu XL, et al. Diver CE versus Guardwire Plus for thrombectomy during primary angioplasty for inferior myocardial infarction. Chung Hua Hsin Hsueh Kuan Ping Tsa Chih. 2007;35:461-5. [pmid: 17711691].
162 Wita K, Lelek M, Filipecki A, et al. Microvascular damage prevention with thrombaspiration during primary percutaneous intervention in acute myocardial infarction. Coron Artery Dis. 2009;20:51-7. [pmid: 18997622].
163 Ozaki Y, Nomura M, Nakayama T, et al. Effects of thrombus suction therapy on myocardial blood flow disorders in males with acute inferior myocardial infarction. J Med Invest. 2006;53:167-73. [pmid: 16538011].
164 Ochala A, Smolka G, Wojakowski W, et al. Prospective randomised study to evaluate effectiveness of distal embolic protection compared to abciximab administration in reduction of microembolic complications of primary coronary angioplasty. Kardiol Pol. 2007;65:672-80. [pmid: 17629829].
165 Yamamoto S, Kamihata H, Sutani Y, et al. Effects of intravenous administration of tissue plasminogen activator before thrombectomy in patients with acute myocardial infarction. Circ J. 2006;70:243-7. [pmid: 16501287].
166 Beran G, Lang I, Schreiber W, et al. Intracoronary thrombectomy with the X-sizer catheter system improves epicardial flow and accelerates ST-segment resolution in patients with acute coronary syndrome: a prospective, randomized, controlled study. Circulation. 2002;105:2355-60. [pmid: 12021220].
167 Beran G, Lang I, Syeda B, et al. Intracoronary thrombectomy in acute coronary syndrome with a new percutaneous device: The Vienna X-Sizer study. Am J Cardiol. 2001;88:TCT189.
168 Kanaya T, Oida A, Sugimura H, et al. A distal protection method combined with thrombectomy and stenting prevents slow flow phenomenon following coronary artery intervention for patients with acute myocardial infarction. Circulation. 2003;107:P22.
169 Tamhane UU, Chetcuti S, Hameed I, et al. Safety and efficacy of thrombectomy in patients undergoing primary percutaneous coronary intervention for acute ST elevation MI: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord. 2010;10:10. [pmid: 20187958].
170 Inaba Y, Chen JA, Mehta N, et al. Impact of single or multicentre study design on the results of trials examining the efficacy of adjunctive devices to prevent distal embolisation during acute myocardial infarction. EuroIntervention. 2009;5:375-83. [pmid: 19736164].
171 Burzotta F, De Vita M, Gu YL, et al. Clinical impact of thrombectomy in acute ST-elevation myocardial infarction: an individual patient-data pooled analysis of 11 trials. Eur Heart J. 2009;30:2193-203. [pmid: 19726437].
172 De Vita M, Burzotta F, Biondi-Zoccai GG, et al. Individual patient-data meta-analysis comparing clinical outcome in patients with ST-elevation myocardial infarction treated with percutaneous coronary intervention with or without prior thrombectomy. ATTEMPT study: a pooled Analysis of Trials on ThrombEctomy in acute Myocardial infarction based on individual PatienT data. Vasc Health Risk Manag. 2009;5:243-7. [pmid: 19436647].
173 Amin AP, Mamtani MR, Kulkarni H. Factors influencing the benefit of adjunctive devices during percutaneous coronary intervention in ST-segment elevation myocardial infarction: meta-analysis and meta-regression. J Intervent Cardiol. 2009;22:49-60. [pmid: 19141090].
174 Bavry AA, Kumbhani DJ, Bhatt DL. Role of adjunctive thrombectomy and embolic protection devices in acute myocardial infarction: a comprehensive meta-analysis of randomized trials. Eur Heart J. 2008;29:2989-3001. [pmid: 18812323].
175 Burzotta F, Testa L, Giannico F, et al. Adjunctive devices in primary or rescue PCI: a meta-analysis of randomized trials. Int J Cardiol. 2008;123:313-21. [pmid: 17383756].
176 De Luca G, Dudek D, Sardella G, et al. Adjunctive manual thrombectomy improves myocardial perfusion and mortality in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction: a meta-analysis of randomized trials. Eur Heart J. 2008;29:3002-10. [pmid: 18775918].
177 Grines CL, Nelson TR, Safian RD, et al. A Bayesian meta-analysis comparing AngioJet thrombectomy to percutaneous coronary intervention alone in acute myocardial infarction. J Intervent Cardiol. 2008;21:459-82. [pmid: 19018943].
178 De Luca G, Suryapranata H, Stone GW, et al. Adjunctive mechanical devices to prevent distal embolization in patients undergoing mechanical revascularization for acute myocardial infarction: a meta-analysis of randomized trials. Am Heart J. 2007;153:343-53. [pmid: 17307410].
179 Kunadian B, Dunning J, Vijayalakshmi K, et al. Meta-analysis of randomized trials comparing anti-embolic devices with standard PCI for improving myocardial reperfusion in patients with acute myocardial infarction. Catheter Cardiovasc Interv. 2007;69:488-96. [pmid: 17286249].
180 Masotti M, Salazar H, Kiamco R, et al. Is the routine use of thrombectomy and distal protection devices of clinical benefit in acute myocardial infarction? A meta-analysis. Am J Cardiol. 2007;99:5F. [pmid: 17196453].
181 Mongeon F, Belisle P, Joseph L, et al. Primary percutaneous coronary intervention in acute myocardial infarction with or without thrombectomy: a meta-analysis. J Am Coll Cardiol. 2008;51:A243.
182 Brahmbhatt T, Marks DS, Cinquegrani M, et al. Improved angiographic and electrocardiographic, but not clinical outcomes, following coronary thrombectomy in patients with ST elevation myocardial infarction: a meta-analysis. Am J Cardiol. 2006;98:61M.
183 Salazar H, Masotti M, Ruiz-Salmeron R, et al. Role of thrombectomy and distal protection devices in acute myocardial infarction. Is their routine use of clinical benefit? A meta-analysis. Eur Heart J. 2006;27:770-1. [pmid: 16449246].
184 Salazar H, Masotti M, Kiamco R, et al. Role of thrombectomy and distal protection devices in acute myocardial infarction. Is their routine use of clinical benefit? A meta-analysis. Circulation. 2006;114:516.
185 Qayyum R, Khalid MR, Adomaityte J, et al. Distal protection devices during percutaneous coronary intervention are effective in reducing death or recurrent myocardial infarction in saphenous vein grafts but not in acute myocardial infarction: A meta-analysis. J Am Coll Cardiol. 2006;47:251A-2A.
186 Masotti M, Salazar H, Freixa X, et al. Role of embolic protection devices in acute myocardial infarction. Is their routine use of clinical benefit at 6 months?. Circulation. 2008;118:E431.
187 Masotti M, Salazar H, Kiamco R, et al. Embolic Protection Devices in Acute Myocardial Infarction. Do They Confer the Same Clinical Benefit?. Circulation. 2008;118:S974.
188 Salazar H, Freixa X, Bellera N, et al. Role of embolic protection devices in acute myocardial infarction. Is their routine use of clinical benefit at six months?. J Am Coll Cardiol. 2008;51:A208.
189 Mongeon FP, Belisle P, Joseph L, et al. Adjunctive thrombectomy for acute myocardial infarction: A bayesian meta-analysis. Circ Cardiovasc Interv. 2010;3:6-16. [pmid: 20118149].
190 Lookstein RA, Lewis S. Distal embolic protection for infrainguinal interventions: how to and when?. Tech Vasc Interv Radiol. 2010;13:54-8. [pmid: 20123433].