# Peer Reviewers

Deepak Bhatt, M.D., M.P.H., FACC

Associate Professor of Medicine

Harvard Medical School

Chief of Cardiology

VA Boston Healthcare System

Boston, MA

Hemant Kulkarni, M.B.B.S., M.D.

Associate Professor of Medicine

University of Texas Health Science Center

Director, Biostatistical Core

Veterans Affairs Center for Research

San Antonio, TX