# Methods

## Input From Stakeholders

The EPC drafted a topic refinement document with proposed key questions after consult with Key Informants. Our Key Informants included six physicians: two provided methods expertise, two represented the payer's perspective, one provided the local interventional cardiologist's perspective, and the last provided both an interventional cardiologist and American College of Cardiology perspective. Our Key Informants did not have financial or other declared conflicts. The public was invited to comment on the topic refinement document and key questions. After reviewing the public commentary, responses to public commentary, proposed revisions to the key questions, and a preliminary protocol was generated and reviewed with the Technical Expert Panel. The aforementioned Key Informants constituted our Technical Expert Panel and provided feedback on the feasibility and importance of our approach and provided their unique insight. Again, no conflict of interest was identified. The draft CER underwent peer review and public comments with revisions made based on commentary.

## Searching for the Evidence: Literature Search Strategies for Identifying Relevant Studies to Answer the Key Questions

The following statement describing the population, intervention, comparator and outcomes (PICO) was used to design the literature search: Does the use of adjunctive devices in ACS patients (i.e. catheter aspiration, mechanical thrombectomy, distal balloon embolic protection, distal filter embolic protection, proximal balloon embolic protection, embolic protection devices combined) in combination with PCI of native vessels affect surrogate outcomes (e.g., ST-segment resolution, MBG, TIMI-3 flow, ejection fraction and distal embolization), health (mortality, MACE, health-related quality-of-life) or safety outcomes (coronary dissection, coronary perforation, prolonged procedure time) as compared to PCI alone? We conducted a computerized literature search of the Cochrane Library and Medline databases for both RCTs and observational studies that were published from January 1996 through March 2010. The search was restricted to 1996 and later to reflect contemporary practice. The complete search strategy is included in Appendix A. We did not apply any language restrictions. Additionally, in an attempt to locate unpublished studies and increase the sensitivity of our search, references from identified studies and systematic reviews were reviewed. Abstracts from major cardiology meetings (American Heart Association, American College of Cardiology, European Society of Cardiology, and the Transcatheter Cardiovascular Therapeutics (TCT) Conference of the Cardiovascular Research Foundation) and from the TCTMD (http://www.tctmd.com), the CardioSource Plus (http://www.cardiosource.com), and ClinicalTrials.gov (http://www.clinicaltrials.gov) web sites were searched and reviewed. The literature search was updated in March 2011 using the same search strategy. Scientific information packets for relevant devices were requested by the Scientific Resource Center.

## Criteria for Inclusion and Exclusion of Studies in the Review

Two independent reviewers assessed studies for inclusion in a parallel manner by using criteria defined a priori. RCTs or controlled observational studies that enrolled a total of ≥500 patients were eligible for inclusion if they (1) compared the use of adjunctive devices (i.e., catheter aspiration, mechanical thrombectomy, distal balloon embolic protection, distal filter embolic protection, proximal balloon embolic protection) to remove thrombi or protect against distal embolization versus a control (active or nonactive) before PCI, (2) included only patients with ACS, (3) enrolled only patients with a target lesion(s) in native vessels (studies with less than five percent of patients with target vessel lesions in saphenous vein grafts were included), and (4) reported data on at least one prespecified patient morbidity (ST-segment resolution, MBG, TIMI-3 blood flow, ejection fraction, distal embolization, MACE), mortality, safety (coronary dissection, coronary perforation, prolonged procedure time), or health-related quality-of-life outcome. Observational studies that enrolled <500 subjects total were excluded from Key Questions 1 and 2 because this range contains small initial experiences not representative of current practice and with numerous RCTs already in existence within this smaller sample size range, small studies were thought to be less helpful in defining the applicability of evidence in a tangible way. Observational studies that enrolled <500 subjects total were used to address Key Question 3 if they reported multivariable adjusted results depicting the effect of prespecified patient characteristics on intermediate or terminal outcomes. Systematic reviews with meta-analyses which met the inclusion criteria were manually reviewed for additional references.

## Data Extraction and Data Management

Two reviewers used a standardized data extraction tool to independently extract study data. (Appendix B) Data extracted from each study included interventions, study design, inclusion and exclusion criteria, methodological quality criteria, study population, baseline patient characteristics, use of concurrent standard medical therapies, data needed to assess for applicability (as specified in Applicability of Evidence below), and prespecified benefits to harms (as specified in the Key Questions). Previous systematic reviews with meta-analysis addressing the same or similar topic and identified during our literature search are described in Appendix C for completeness.

## Assessment of Methodological Quality of Individual Studies

Validity assessment was performed by two reviewers using the recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.22 Each study was assessed for the following individual criteria: comparable study groups at baseline, detailed description of study outcomes, blinding of outcome assessors, intent-to-treat analysis, description of participant withdrawals (percent followup), and potential conflict of interest. Additionally, RCTs were assessed for randomization technique. Observational studies were assessed for sample size, participant selection method, exposure measurement method, potential design biases, and appropriate analyses to control for confounding. Studies were then given an overall quality score of good, fair, or poor (Table 4).

Table 4 Summary ratings of quality of individual studies

Quality Rating | Definition
Good (low risk of bias) | These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality include the following: a formal randomized, controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 30 percent dropout; and clear reporting of dropouts.
Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

## Data Synthesis

We qualitatively examined data from all identified studies. For each outcome, we conducted separate analyses of studies that compare each individual adjunctive device type (e.g., catheter aspiration, mechanical thrombectomy, distal filter embolic protection, distal balloon embolic protection, proximal balloon embolic protection) with control and studies in which different adjunctive device types were compared to each other. We conducted separate analyses for studies that enrolled patients experiencing only STEMI, studies that enrolled patients experiencing NSTEMI or UA, and studies that enrolled patients with mixed ACS (STEMI or NSTEMI or UA). We conducted meta-analyses when two or more RCTs that were adequate for data pooling were available for any outcome. Observational studies were not pooled with RCTs and were assessed in a qualitative fashion only. For dichotomous outcomes, weighted averages are reported as relative risks (RR) and risk differences (RD) with associated 95 percent confidence intervals. As pooled RD may provide unstable estimates when control rates are heterogeneous, we report the control rate range to aid in interpretation. For intermediate outcomes depicting the extent of myocardial reperfusion (MBG, TIMI blood flow and ST-segment resolution), we defined attainment of optimal myocardial reperfusion as a MBG-3 or TIMI-3 blood flow (or a MBG or TIMI blood flow of at least two in studies not reporting the other endpoint) and complete ST-segment resolution as 70 percent resolution in peak ST-segments (or at least 50 percent resolution in studies not reporting the other endpoint). When possible we used results for ST-segment resolution reported at 60 minutes, although when unavailable, we utilized data reported immediately after the procedure or up to 90 minutes after. For studies with multiple time points, we used the time closest to 60 minutes.

For final health outcomes, we used the maximum duration of followup, defined as the longest time point from the procedure where the occurrence of a final health outcome is reported, as the base case analysis. As heterogeneity between included studies was expected, a DerSimonian and Laird random-effects model was used when pooling data and calculating RR, RD, and 95 percent confidence intervals.23 Automatic „zero cell‟ correction was used for studies with no events for a particular outcome occurring in one group. Studies with no events occurring in both treatment and control groups were excluded from meta-analysis. When pooling continuous outcomes, weighted mean differences along with 95 percent confidence intervals were calculated using a DerSimonian and Laird random-effects model.23

Statistical heterogeneity was addressed by using the both the Cochrane Q-statistic and the I^2^ statistic. The I^2^ statistic assesses the degree of inconsistency not due to chance across studies and ranges from 0-100 percent with the higher percentage representing a higher likelihood of the existence of heterogeneity. Whereas categorization of I^2^ values may not be appropriate in all situations, an I^2^ value of >50 percent has been regarded as representative of important statistical heterogeneity. Egger's weighted regression statistic was used to assess for the presence of publication bias.24 Statistics were performed using StatsDirect statistical software, version 2.7.8 (StatsDirect Ltd., Cheshire, England). For all analyses, a p-value of <0.05 was considered statistically significant.

To assess the effect of heterogeneity (both clinical and methodological) on the conclusions of our meta-analysis, we conducted multiple subgroup and sensitivity analyses. These analyses were conducted to assess the methodological study quality (analyses limited to “good” studies only) and duration of followup on the efficacy of adjunctive devices. More specifically for duration of followup, data representing the maximal extent of clinical followup and at different extents of clinical followup (in-hospital, ≥ 30 days but <180 days, ≥ 180 days but < 365 days, and ≥ 365 days), were pooled in separate analyses.

For Key Question 3, patient demographics (age, sex, and ethnicity), baseline patient health status (smoking history, history of diabetes, ejection fraction, ischemia time, prePCI TIMI flow, presence of thrombus-containing lesion, and location infarct-related artery), and concomitant treatment characteristics (rescue PCI, administration of glycoprotein IIb/IIIa inhibitors, and direct stenting) were assessed for their impact on the efficacy of adjunctive devices. Data from RCTs, controlled observational studies and individual patient data meta-analyses were utilized. For RCTs or controlled observational studies, data from subgroup analyses were abstracted, and when not reported, p-values for interaction between subgroups were calculated to aid in interpretation (no adjustment for multiple hypothesis testing was performed).25 Due to the limited amount of data reported for each patient demographic/health status in the literature as well as observed heterogeneity within time points and definitions of outcomes, meta-analyses were not conducted for this key question. Data from single-arm (all patients receiving an adjunctive device) observational study reports were only included if they conducted multivariate analysis to identify independent predictor of prespecified outcomes.

## Grading the Evidence for Each Key Question

We used the Grading of Recommendations Assessment, Development and Evaluation system to assess the strength of evidence for each outcome of interest separately. This system uses four required domains—risk of bias, consistency, directness, and precision. Additional domains were not assessed because they were deemed irrelevant to this review. All assessments were made by two investigators, with disagreements resolved through discussion. When a large preponderance of data available for an outcome was of good quality, the strength of evidence was not inherently downgraded because of a small number of poorer quality trials or studies. The evidence pertaining to each key question was classified into four broad categories: high, moderate, low grade or insufficient (Table 5). Below we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report.

Table 5 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Risk of bias. Risk of bias is the degree to which the included studies for any given outcome or comparison has a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations. Whether the study was designed as an RCT or an observational study will be recorded. Studies were ranked as having no limitations, serious limitations, or very serious limitations.

Consistency. Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. We assessed whether or not the effect sizes were on the same side of unity; whether the range of effect sizes was narrow, and the degree of statistical heterogeneity in evaluating consistency. We ranked this domain as no inconsistency, serious inconsistency, and very serious inconsistency. When only a single study was included, consistency was not judged.

Directness. Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most important health outcomes. We ranked this domain as no indirectness, serious indirectness, and very serious indirectness.

Precision. Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. For example, when a meta-analysis is performed, we will evaluate the confidence interval around the summary effect size. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g. both clinically important superiority and inferiority), a circumstance that will preclude a conclusion.

## Applicability of Evidence

To be designated an effectiveness study, it had to meet five of the following seven criteria: used a primary care population, used less-stringent eligibility criteria, assessed final health outcomes, had an adequate study duration with clinically relevant treatment modalities, assessed adverse events, had an adequate sample size, and used intention-to-treat analysis.26 Studies meeting fewer than five criteria were classified as efficacy studies and deemed to have less applicability. Table 6 identifies the factors that are important for determining applicability; those factors that were extracted into evidence tables for every study we evaluated. By using all of the applicable studies to answer a key question, the applicability of the body of evidence was then determined and reported separately and qualitatively for each outcome of interest.

Table 6 Applicability PICOTS and data to extract

Feature | Condition that limits applicability | Features to be extracted into evidence table
Population | Differences between patients in the study and the community | Eligibility criteria, demographics
Population | Events rates markedly different than in the community | Event rates in treatment and control groups
Intervention | Treatment not reflective of current practice | Type of device, device name
Comparator | Use of substandard alternative therapy | Type of comparator
Outcomes | Intermediate end points, brief followup periods, improper definitions for outcomes, composite end points | Outcomes (benefits to harms) and how they were defined
Settings | Settings where standards of care differ markedly from setting of interest | Clinical setting and geographic setting