# Key Informants

Amit Amin, M.D., M.S.C.R.

American Heart Association

Outcomes and Interventional Research Fellow

St. Luke's Hospital and Mid-America Heart Institute

Kansas City, MO

Joseph Chin, M.D., M.S.

Medical Officer

Coverage and Analysis Group

Centers for Medicare & Medicaid Services

Woodlawn, MD

Kenneth Grossman, M.D.

Associate Medical Director

General Electric

Fairfield, CT

Francis Kiernan, M.D.

Director, Cardiac Laboratory

Hartford Hospital

Hartford, CT

Hemant Kulkarni, M.B.B.S., M.D.

Associate Professor of Medicine

University of Texas Health Science Center

Director, Biostatistical Core

Veterans Affairs Center for Research

San Antonio, TX

Raymond McKay, M.D.

Director, Interventional Cardiology

Hartford Hospital

Hartford, CT

Janet Wright, M.D., FACC

Vice President

Science & Quality

American College of Cardiology

Washington, DC