# Introduction

## Background

Coronary heart disease (CHD) is a leading cause of morbidity and mortality in the United States. According to the American Heart Association statistics, >650,000 deaths were attributed to CHD in 2003. Moreover, treatment costs for CHD represent the largest healthcare expenditure for a single disease in the United States.1

Acute coronary syndromes (ACSs), which include the clinical entities of unstable angina (UA), nonST-segment elevation myocardial infarction (NSTEMI), and ST-segment elevation myocardial infarction (STEMI), account for more than 1.5 million hospital admissions annually in the United States alone. Approximately 1 million of these admissions are classified as UA/NSTEMI and approximately 500,000 are STEMI.2

Percutaneous coronary intervention (PCI) has revolutionized the management of angina and myocardial infarction (MI), frequently negating the need for coronary bypass surgery and permitting a more rapid return to normal activities. The clinical use of PCI is reflected in the number of patients who undergo this procedure. In the United States alone, 664,000 procedures were performed in 652,000 patients in 2003, representing a 326 percent increase from the number of procedures performed in 1987.^1^

Coronary stents and adjunctive pharmacologic agents—including glycoprotein IIb/IIIa receptor inhibitors and thienopyridines—have improved the effect of PCI establishing near normal antegrade blood flow in the vast majority of patients.1,3-5

However, dislodgement of atherothrombotic material from coronary lesions during PCI can result in distal embolization that leads to what is commonly referred to as the “no-reflow phenomenon.” This phenomenon, characterized by inadequate flow at the cardiac tissue level despite patent coronary vessels is often defined as (1) a thrombolysis in myocardial infarction (TIMI) flow grade ≤2 (Table 1) despite vessel patency and the absence of dissection, spasm or distal macroembolus, (2) a myocardial blush grade (MBG) of 0 or 1 (Table 2), or (3) a contrast perfusion defect observed upon myocardial contrast echocardiography. Depending on the exact clinical definition used, the incidence of no-reflow has been found to range from 12 to 39 percent,1,3 and may be associated with advanced age, presence of diabetes mellitus, left ventricular systolic dysfunction, longer ischemic times, poor initial TIMI flow grades, and anterior myocardial infarction.6

Table 1 Thrombolysis in myocardial infarction (TIMI) Flow Grading System7

Grade 0 | Complete occlusion of the infarct-related artery
Grade 1 | Some penetration of contrast material beyond the point of obstruction but without perfusion of the distal coronary bed
Grade 2 | Perfusion of the entire infarct vessel into the distal bed but with delayed flow compared with a normal artery
Grade 3 | Full perfusion of the infarct vessel with normal flow

Table 2 Myocardial blush grade8

Grade 0 | Failure of dye to enter the microvasculature. Either minimal or no ground glass appearance (“blush”) or opacification of the myocardium in the distribution of the culprit artery indicating lack of tissue level perfusion.
Grade 1 | Dye slowly enters but fails to exit the microvasculature. There is the ground glass appearance (“blush”) or opacification of the myocardium in the distribution of the culprit lesion that fails to clear from the microvasculature, and dye staining is present on the next injection (approximately 30 seconds between injections).
Grade 2 | Delayed entry and exit of dye from the microvasculature. There is the ground glass appearance (“blush”) or opacification of the myocardium in the distribution of the culprit lesion that is strongly persistent at the end of the washout phase (i.e. dye is strongly persistent after 3 cardiac cycles of the washout phase and either does not or only minimally diminishes in intensity during washout).
Grade 3 | Normal entry and exit of dye from the microvasculature. There is the ground glass appearance (“blush”) or opacification of the myocardium in the distribution of the culprit lesion that clears normally, and is either gone or only mildly/moderately persistent at the end of the washout phase (i.e. dye is gone or is mildly/moderately persistent after 3 cardiac cycles of the washout phase and noticeably diminishes in intensity during the washout phase), similar to that in an uninvolved artery. Blush that is of only mild intensity throughout the washout phase but fades minimally is also classified as grade 3.

A higher rate of adverse outcomes has been noted in patients with no-reflow, including larger infarcts, more significant left ventricular systolic dysfunction, and an increased risk of major adverse cardiovascular events (MACE) or death. Numerous adjunctive devices have been developed in an attempt to improve clinical outcomes by removing thrombi and to protect against distal embolization during PCI.9 These devices utilize different technologies and can be broadly classified as catheter aspiration, mechanical thrombectomy, or embolic protection devices (i.e., distal embolic balloon or filter protection devices or proximal embolic balloon protection devices) (Table 3).10

Table 3 Thrombectomy and embolic protection devices used in the randomized controlled trials included in the quantitative synthesis

Device Type (Mechanism) | Device Name | Manufacturer | FDA Approved Indication(s)
Catheter Aspiration | Diver ™ | Invatec | Not/no longer available for sale in US
Catheter Aspiration | Diver™ CE | Invatec | Not/no longer available for sale in US
Catheter Aspiration | Export^®^ | Medtronic | Removal/aspiration of embolic material (thrombus/debris) from vessels of the arterial system, and to sub-selectively infuse/deliver diagnostic or therapeutic agents with or without vessel occlusion
Catheter Aspiration | Pronto™ | Vascular solutions | Removal of emboli and thrombi from vessels in the arterial or deep venous system and to infuse diagnostic or therapeutic agents
Catheter Aspiration | Rescue™ | Boston Scientific | Not/no longer available for sale in US
Catheter Aspiration | Thrombobuster^®^ | Kaneka Medix | No FDA approved indication
| TransVascular Aspiration Catheter^®^ (TVAC) | Nipro | No FDA approved indication
Mechanical Thrombectomy | AngioJet^®^ | MEDRAD Interventional / Possis | Removal of thrombus in the treatment of patients with symptomatic coronary artery or saphenous vein graft lesions in vessels ≥ 2 mm in diameter prior to balloon angioplasty or stent placement
Mechanical Thrombectomy | X-Sizer^®^ | ev3 | Removal of thrombus in synthetic hemodialysis access grafts
Distal Filter Embolic Protection | FilterWire EX™ | Boston Scientific | Use as a guidewire and embolic protection system to contain and remove embolic material (thrombus/debris) while performing percutaneous transluminal coronary angioplasty or stenting procedures in coronary saphenous vein bypass grafts with reference vessel diameters of 3.5 to 5.5 mm
Distal Filter Embolic Protection | FilterWire EZ™ | Boston Scientific | Use as a guidewire and embolic protection system to contain and remove embolic material (thrombus/debris) while performing angioplasty and stenting procedures in coronary saphenous vein bypass grafts and carotid arteries
Distal Filter Embolic Protection | SpideRX™ | ev3 | No longer available for sale in US
Distal Filter Embolic Protection | AngioGuard™ | Cordis | No longer available for sale in US
Distal Filter Embolic Protection | AngioGuard™ XP | Cordis | Use as a guidewire and embolic protection system to contain and remove embolic material (thrombus/debris) while performing angioplasty and stenting procedures in carotid arteries
Distal Filter Embolic Protection | Filtrap | Nipro | No FDA approved indication
Distal Balloon Embolic Protection | PercuSurge GuardWire^®^ | Medtronic | Not/no longer available for sale in US
Distal Balloon Embolic Protection | PercuSurge GuardWire™ Plus | Medtronic | Use to contain and aspirate embolic material (thrombus/debris) while performing percutaneous transluminal coronary angioplasty or stenting procedures
Proximal Balloon Embolic Protection | Proxis™ | St. Jude Medical | Use as a proximal embolic protection system to prevent distal release of and to aspirate embolic material (thrombus/debris) in saphenous vein coronary bypass graft(s) during percutaneous transluminal coronary angioplasty and/or stenting procedures and to control the flow of fluids in the coronary and peripheral vasculature

Distal embolic protection devices are recommended to be used in patients undergoing PCI of saphenous vein grafts due to previously demonstrated ability to reduce MACE.1,3 However, use of embolic protection devices in STEMI has been less well supported mainly because of underpowered clinical trials that evaluated intermediate markers.3 More recently, larger randomized controlled trials (RCTs) of patients with STEMI have evaluated MACE as an end point and followed patients beyond hospital discharge (typically 3 to 12 months) but have given conflicting results.11-21 Thus, the comparative effectiveness and safety of these devices is unclear and needs to be systematically evaluated.

## Objective

To perform a comparative effectiveness review examining the benefits to harms associated with using adjunctive devices to remove thrombi or protect against distal embolization in patients with ACS who are undergoing PCI of native vessels.

## Key Questions

Key Question 1 In patients with ACS who are undergoing PCI of native vessels, what are the comparative effects of adjunctive devices from different classes (e.g., catheter aspiration, mechanical thrombectomy, distal balloon embolic protection, distal filter embolic protection, proximal balloon embolic protection) on intermediate outcomes (e.g., ST-segment resolution, MBG, TIMI-3 flow, ejection fraction and distal embolization) and final health outcomes (mortality, MACE, health-related quality-of-life)?
Key Question 2 In patients with ACS who are undergoing PCI of native vessels, how does the rate and type of adverse events (e.g., coronary dissection, coronary perforation, prolonged procedure time) differ between device types when compared to PCI alone?
Key Question 3 In patients with ACS who are undergoing PCI of native vessels, which patient characteristics (e.g., gender, age, ethnicity, diabetes, smoker, ejection fraction, primary or rescue PCI, use of glycoprotein IIb/IIIa inhibitors, ischemia time, presence of a thrombus-containing lesion, infarct-related artery and prePCI TIMI flow, use of direct stenting) affect outcomes?

## Analytic Framework

The analytic framework used is shown in Figure 1.

Figure 1 Analytic framework for adjunctive devices to remove thrombi and protect against distal embolization in patients with acute coronary syndromes who are undergoing percutaneous coronary intervention of native vessels

Abbreviations: ACS = acute coronary syndrome; KQ=key question; MACE=major adverse cardiovascular events; MBG=myocardial blush grade; PCI=percutaneous coronary intervention; STSR=ST-segment resolution; TIMI=thrombolysis in myocardial infarction; TR=target revascularization

This analytic framework figure is intended as an overview only. The links between the use of an intervention in a population and outcomes are described. The population includes all patients with ACS undergoing PCI of native vessels and will be assessed separately by gender, age, ethnicity, diabetes, smoker, ejection fraction, primary or rescue PCI, use of glycoprotein IIb/IIIa inhibitors, ischemia time, presence of thrombus-containing lesion, infarct-related artery and pre-PCI TIMI flow, use of direct stenting. The intervention is the use of an adjunctive thrombectomy or embolic protection device. The outcomes are separated into adverse events, intermediate outcomes, and final health outcomes. The adverse events of note include coronary dissection, perforation and prolonged procedure time. The intermediate outcomes included ST-segment resolution, MBG, post-PCI TIMI-3 flow, ejection fraction, distal embolization and no-reflow. The final health outcomes include mortality, MACE (including re-infarction, target revascularization, and stroke) and impact of therapy on health-related quality-of-life.