# Future Research

## Limitations of Current Research

The use of thrombus removal and embolic protection devices hold promise in the adjunctive treatment of patients with ACS undergoing primary percutaneous coronary intervention. However, to truly discern the role of these devices in contemporary practice, a number of important research questions need to be answered.

While two direct comparative randomized trials had been conducted and evaluated for multiple endpoints, one comparing one catheter aspiration device to another and one comparing a catheter aspiration device to an embolic protection device, no significant differences were found and the trials were vastly underpowered to evaluate for final health outcomes and underpowered to evaluate for intermediate health outcomes as well.

In our analysis, we found that for many endpoints, nonsignificant increases or decreases were found versus control, even when we evaluated compound endpoints, used the maximum duration of followup, and combined three different types of embolic protection devices together. All of these were strategies to enhance power to detect differences between groups but by and large, did not provide adequate power. Ultimately, the impact of using these devices on long term final health outcomes versus control needs to be determined.

Applicability of the trials was in the low to moderate range for almost all outcomes because the trials were mostly conducted outside of the United States. It will be important to determine if the devices are equally effective in the hands of average interventional cardiologists in the United States. In addition, it is unclear how much experience the interventional cardiologists had in performing the procedures before enrolling in the clinical trials. It is unclear whether the use of the devices by average interventional cardiologists will result in a different balance of benefits to harms versus the more experienced, high volume interventional cardiologists.

Given the inadequate power in overall analyses or lack of data, we cannot determine the impact of therapy in subpopulations (e.g., gender, age, ethnicity, diabetes, smoker, ejection fraction, primary or rescue PCI, use of glycoprotein IIb/IIIa inhibitors, ischemia time, presence of thrombus-containing lesion, infarct-related artery and prePCI TIMI flow, use of direct stenting).

Based on these research gaps we propose the following avenues for future research.

## Future Avenues for Research

### Clinical Trials

- We believe that additional multicenter, randomized, placebo-controlled trials should be conducted to determine the impact of adjunctive clot removal or embolic protection devices on final health outcomes using a long term followup.
  ○ Such trials should have adequate representation of interventional cardiologists from the United States and include both tertiary academic medical centers and large community based hospitals as well.
  ○ Even if the trials are not large enough to determine efficacy in subgroups (e.g., gender, age, ethnicity, diabetes, smoker, ejection fraction, primary or rescue PCI, use of glycoprotein IIb/IIIa inhibitors, ischemia time, presence of thrombus-containing lesion, infarct-related artery and prePCI TIMI flow, use of direct stenting); such data should be recorded and included in the results so future comparative effectiveness reviews could pool these results and determine if the benefits or harms are uniformly distributed across the population or are centered within a certain subgroup.
  ○ Conducting these additional clinical trials would facilitate the conduction of mixed treatment meta-analyses or individual patient data meta-analyses to estimate the comparative effectiveness of different device classes.
- To truly determine the comparative effectiveness, the devices found to have the best balance of benefits to harms compared with standard PCI should be directly compared in a multicenter, randomized, active controlled trial to determine the impact of adjunctive clot removal or embolic protection devices on final health outcomes using a long term followup.
  ○ Such a trial should have adequate representation of interventional cardiologists from the United States and include both tertiary academic medical centers and large community based hospitals as well.
  ○ Even if the trial is not large enough to determine efficacy in subgroups; such data should be included in the results.
  ○ Along with additional placebo controlled trials, conducting direct comparative clinical trials would facilitate the conduction of mixed treatment meta-analyses or individual patient data meta-analyses to estimate the comparative effectiveness of device classes that are and are not being directly compared.

### Observational Studies

- Future observational studies should determine if certain subpopulations may have accentuated or attenuated benefits or harms and whether benefits or harms differ between high volume academic medical centers and lower volume community hospital.
- Electronic medical records can be used as a source of data for future observational and effectiveness studies.