# Discussion

The determination of the balance of benefits to harms is difficult because many of the final health outcome and adverse event evaluations are underpowered. We cannot know for certain whether the nonsignificant increases or decreases are due to a real effect or to chance. The applicability of the body of evidence is highest for patients with STEMI undergoing primary PCI of the native vessels. Data is more highly applicable to male patients versus female patients, because of the enrollment of a consistently higher percentage of males across trials. The majority of data is derived from trials and studies conducted outside of the United States evaluating devices that are not currently available in the United States, therefore the applicability is limited. Overall, applicability is low in patients with other ACSs or in patients undergoing rescue PCI.

In the catheter aspiration trials, the risk of MACE and coronary dissection were significantly lower in the overall analysis and the good quality trial analyses. The risk of mortality, myocardial infarction, stroke, target revascularization and side branch occlusion were not significantly different versus control. Eight of nine trials and one controlled observational study found a nonsignificant prolongation of the time needed to conduct the PCI procedure versus control. Intermediate health outcomes showed significant reductions in distal embolization and no reflow and significantly more patients experienced ST segment resolution, higher MBG, and near normal (TIMI-3) blood flow though the target vessel versus control. As such, more research is needed to truly determine the balance of benefits to harms.

Mechanical thrombectomy device use did not result in any significant differences in the risk of mortality, stroke, MACE, coronary dissection, and coronary perforation in the overall analyses and analyses limited to good quality trials. However, these devices significantly increased the time needed to conduct the PCI procedure in three trials. While the risk of myocardial infarction, target revascularization, mortality and MACE were no significantly different versus control, these findings may be misleading since many of the trials evaluating this procedure versus control had a shorter duration of follow-up. When we evaluated mortality and MACE in studies of 365 days or longer, there was no significant difference in mortality risk although there was a significant reduction in MACE, based on the results of a single trial. Unlike with catheter aspiration devices, there are no significant beneficial effects on intermediate health outcomes and while most are in the right direction of effect, the chance of achieving near normal (TIMI-3) blood flow was not significantly different versus control. As such, more research is needed to truly determine the balance of benefits to harms with mechanical thrombectomy devices.

The use of embolic protection devices was based on a limited number of studies and one significant finding (distal filter on target revascularization) on final health outcomes was seen in overall analyses or those limited to good quality trials. It was difficult to assess the impact on final health outcomes and intermediate outcomes for these devices. In STEMI, distal balloon devices significantly increased the chance of achieving a MBG-3, near normal (TIMI-3) blood flow but did not significantly impact the achievement of ST-segment resolution, prevention of no reflow, or the risk of distal embolization. Distal filter devices did not significantly impact ST-segment resolution, distal embolization, no reflow, attainment of near normal (TIMI-3) blood flow, or MBG. There was a paucity of trials available to evaluate adverse events with any of the embolic protection devices. The only significant findings was an increased time to perform a PCI procedure for all three types of embolic protection devices individually and when evaluated all together versus control. As such, the balance of benefits to harms cannot be determined for these device classes.

Given the inadequate power in overall analyses or lack of data, we could not definitively determine the impact of therapy in subpopulations. No data was available to determine if the results differed based on ethnicity or ejection fraction. Given the available data, the concomitant use of a glycoprotein IIb/IIIa receptor antagonist and a device may be associated with a survival benefit.