# Forest Plots for Results of Final Health Outcomes Analyzed at Individual Time Points

Figure 1 Impact of catheter aspiration devices versus control on in-hospital mortality

Cochran Q: P = 0.832

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on in-hospital mortality versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.23 to 4.08. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The third trial by Ikari and colleagues in 2008 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.16. The fourth trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no deaths occurred in either the treatment or control group and therefore a relative risk could not be calculated. The combined effect of the three trials showed a relative risk of 0.81 with a 95 percent confidence interval of 0.23 to 2.86. The Cochran Q p-value was 0.832, the I-squared value was zero percent and the Egger's p-value could not be evaluated because of too few strata.

Figure 2 Impact of catheter aspiration devices versus control on ≤30 day mortality

Cochran Q: P = 0.961

I^2^: 0%

Egger: P = 0.689

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on ≤30 day mortality versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.23 to 4.08. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The third trial by Chevalier and colleagues in 2008 provided a relative risk of 0.86 with 95 percent confidence interval of 0.25 to 2.89. The fourth trial by Ikari and colleagues in 2008 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.16. The fifth trial by Svilaas and colleagues, also in 2008, provided a relative risk of 0.53 with 95 percent confidence interval of 0.26 to 1.06. The sixth trial by Kaltoft and colleagues in 2006 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.78. The seventh trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no deaths occurred in either the treatment or control group and therefore a relative risk could not be calculated. The eighth trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with 95 percent confidence interval of 0.24 to 4.16. The combined effect of the seven trials showed a relative risk of 0.65 with a 95 percent confidence interval of 0.39 to 1.10. The Cochran Q p-value was 0.961, the I-squared value was zero percent and the Egger's p-value was 0.689.

Figure 3 Impact of catheter aspiration devices versus control on 30-day mortality

Cochran Q: P = 0.892

I^2^: 0%

Egger: P = 0.976

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 30 day mortality. The first trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with 95 percent confidence interval of 0.00 to 3.76. The second trial by Chevalier and colleagues in 2008 provided a relative risk of 0.86 with a 95 percent confidence interval of 0.25 to 2.89. The third trial by Svilaas and colleagues, also in 2008, provided a relative risk of 0.53 with a 95 percent confidence interval of 0.26 to 1.06. The fourth trial by Kaltoft and colleagues in 2006 provided a relative risk of 0.33 with a 95 percent confidence interval 0.00 to 3.78. The fifth trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.24 to 4.16. The combined effect of the five trials showed a relative risk of 0.61 with a 95 percent confidence interval of 0.35 to 1.07. The Cochran Q p-value was 0.892, the I-squared value was zero percent and the Egger's p-value was 0.976

Figure 4 Impact of catheter aspiration devices versus control on 180-day mortality

Cochran Q: P = 0.391

I^2^: 2.8%

Egger: P = 0.487

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on 180-day mortality versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 1.28 with 95 percent confidence interval of 0.33 to 5.01. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.11 with a 95 percent confidence interval of 0.00 to 0.93. The third trial by Chao and colleagues in 2008 provided a relative risk of 2.76 with 95 percent confidence interval of 0.24 to infinity. The fourth trial by Ikari and colleagues in 2008 provided a relative risk of 1.86 with a 95 percent confidence interval of 0.25 to 14.12. The fifth trial by De Luca and colleagues in 2006, provided a relative risk of 0.22 with 95 percent confidence interval of 0.00 to 2.01. The sixth trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no deaths occurred in either the treatment or control group and therefore a relative risk could not be calculated. The combined effect of the five trials showed a relative risk of 0.89 with a 95 percent confidence interval of 0.31 to 2.51. The Cochran Q p-value was 0.391, the I-squared value was 2.8 percent and the Egger's p-value was 0.487.

Figure 5 Impact of catheter aspiration devices versus control on 365-day mortality

Cochran Q: P = 0.873

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 365- day mortality. The first trial by Svilaas and colleagues provided a relative risk of 0.61 with 95 percent confidence interval of 0.38 to 0.98. The second trial by De Luca and colleagues in 2006 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.16 to 2.95. The combined effect of the two trials showed a relative risk of 0.62 with a 95 percent confidence interval of 0.39 to 0.98. The Cochran Q p-value was 0.873 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 6 Impact of mechanical thrombectomy devices versus control on ≤ 30-day mortality

Cochran Q: P = 0.120

I^2^: 48.7%

Egger: P = 0.329

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on ≤30 day mortality. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.55 with 95 percent confidence interval of 0.17 to 1.73. The second trial by Ali and colleagues in 2006 provided a relative risk of 5.50 with a 95 percent confidence interval of 1.39 to 21.99. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.28 to 3.60. The fourth trial by Antoniucci and colleagues in 2004 was excluded from the meta-analysis because no deaths occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The fifth trial by Napodano and colleagues in 2003 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.47 to 3.32. The combined effect of the four trials showed a relative risk of 1.25 with a 95 percent confidence interval of 0.47 to 3.32. The Cochran Q p-value was 0.120, the I-squared value was 48.7 percent and the Egger's p-value was 0.329.

Figure 7 Impact of mechanical thrombectomy devices versus control on 180-day mortality

Cochran Q: P = 0.090

I^2^: 58.4%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on 180-day mortality. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.61 with 95 percent confidence interval of 0.25 to 1.51. The second trial by Ali and colleagues in 2006 provided a relative risk of 2.80 with a 95 percent confidence interval of 1.07 to 7.38. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 1.52 with a 95 percent confidence interval of 0.47 to 4.88. The combined effect of the three trials showed a relative risk of 1.35 with a 95 percent confidence interval of 0.53 to 3.44. The Cochran Q p-value was 0.090, the I-squared value was 58.4 percent and there were too few strata to calculate the Egger's p-value.

Figure 8 Impact of distal filter embolic protection devices versus control on ≤30 day mortality

Cochran Q: P = 0.805

I^2^: 0%

Egger: P = 0.925

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal filter embolic protection devices on ≤30 day mortality versus control. The first trial by Ito and colleagues in 2010 provided a relative risk of 0.30 with 95 percent confidence interval of 0.00 to 3.30. The second trial by Kelbaeck and colleagues in 2008 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.40 to 2.56. The third trial by Cura and colleagues in 2007 provided a relative risk of 1.00 with 95 percent confidence interval of 0.28 to 3.53. The fourth trial by Guetta and colleagues in 2007 provided a relative risk of 4.81 with a 95 percent confidence interval of 0.51 to infinity. The fifth trial by Lefevre and colleagues in 2004, provided a relative risk of 0.88 with 95 percent confidence interval of 0.09 to 8.17. The combined effect of the five trials showed a relative risk of 1.02 with a 95 percent confidence interval of 0.50 to 2.08. The Cochran Q p-value was 0.805, the I-squared value was 0 percent and the Egger's p-value was 0.925..

Figure 9 Impact of distal balloon embolic protection devices versus control on ≤30-day mortality

Cochran Q: P = 0.716

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices vesus control on ≤30-day mortality. The first trial by Tahk and colleagues in 2008 provided a relative risk of 0.19 with a 95 percent confidence interval of 0.00 to 1.81. The second trial by Muramatsu and colleagues in 2007 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.24 to 2.03. The third trial by Stone and colleagues in 2005 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.24 to 2.09. The combined effect of the three trials showed a relative risk of 0.64 with a 95 percent confidence interval of 0.30 to 1.39. The Cochran Q p-value was 0.716, the I-squared value was zero percent and there were too few strata to calculate the Egger's p-value.

Figure 10 Impact of distal balloon embolic protection devices versus control on 180-day mortality

Cochran Q: P = 0.709

I^2^: 0%

Egger: P = 0.044

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on 180-day mortality. The first trial by Tahk and colleagues in 2008 provided a relative risk of 0.19 with a 95 percent confidence interval of 0.00 to 1.81. The second trial by Hahn and colleagues in 2007 provided a relative risk of 0.5 with a 95 percent confidence interval of 0.00 to 3.88. The third trial by Muramatsu and colleagues in 2007 provided a relative risk of 0.95 with a 95 percent confidence interval of 0.43 to 2.08. The fourth trial by Stone and colleagues in 2005 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.38 to 2.43. The combined effect of the four trials showed a relative risk of 0.86 with a 95 percent confidence interval of 0.48 to 1.57. The Cochran Q p-value was 0.709, the I-squared value was zero percent and the Egger's p-value was 0.044.

Figure 11 Impact of embolic protection devices versus control combined on ≤30 day mortality

Cochran Q: P = 0.931

I^2^: 0%

Egger: P = 0.794

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on ≤30 day mortality versus control. The first trial by Ito and colleagues in 2010 provided a relative risk of 0.30 with 95 percent confidence interval of 0.00 to 3.30. The second trial by Haeck and colleagues in 2009 provided a relative risk of 1.01 with 95 percent confidence interval of 0.18 to 5.69. The third trial by Kelbaeck and colleagues in 2008 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.40 to 2.56. The fourth trial by Tahk and colleagues in 2008 provided a relative risk of 0.19 with 95 percent confidence interval of 0.00 to 1.81.The fifth trial by Cura and colleagues in 2007 provided a relative risk of 1.00 with 95 percent confidence interval of 0.28 to 3.53. The sixth trial by Guetta and colleagues also in 2007 provided a relative risk of 4.81 with a 95 percent confidence interval of 0.51 to infinity. The seventh trial by Muramatsu and colleagues also in 2007, provided a relative risk of 0.69 with a 95 percent confidence interval of 0.24 to 2.03. The eighth trial by Stone and colleagues in 2005 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.24 to 2.09. The ninth trial by Lefevre and colleagues in 2004, provided a relative risk of 0.88 with 95 percent confidence interval of 0.09 to 8.17. The combined effect of the nine trials showed a relative risk of 0.84 with a 95 percent confidence interval of 0.50 to 1.39. The Cochran Q p-value was 0.931, the I-squared value was 0 percent and the Egger's p-value was 0.794.

Figure 12 Impact of embolic protection devices combined versus control on 180-day mortality

Cochran Q: P = 0.836

I^2^: 0%

Egger: P = 0.031

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on 180-day mortality versus control. The first trial by Haeck and colleagues in 2009 provided a relative risk of 0.51 with 95 percent confidence interval of 0.11 to 2.33. The second trial by Tahk and colleagues in 2008 provided a relative risk of 0.19 with 95 percent confidence interval of 0.00 to 1.81.The third trial by Cura and colleagues in 2007 provided a relative risk of 1.25 with 95 percent confidence interval of 0.38 to 4.16. The fourth trial by Hahn and colleagues also in 2007 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.00 to 3.88. The fifth trial by Muramatsu and colleagues also in 2007, provided a relative risk of 0.95 with a 95 percent confidence interval of 0.43 to 2.08. The sixth trial by Stone and colleagues in 2005 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.38 to 2.43. The combined effect of the six trials showed a relative risk of 0.87 with a 95 percent confidence interval of 0.52 to 1.46. The Cochran Q p-value was 0.836, the I-squared value was 0 percent and the Egger's p-value was 0.031.

Figure 13 Impact of embolic protection devices combined versus control on ≤30 day mortality in patients with mixed acute coronary syndromes

Cochran Q: P = 0.677

I^2^: Too few strata

Egger: P = Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices versus control on ≤30-day mortality in patients with mixed acute coronary syndromes. The first trial by Gick and colleagues in 2005 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.14 to 3.27. The second trial by Matsushita and colleagues in 2003 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 2.79. The combined effect of the two trials showed a relative risk of 0.55 with a 95 percent confidence interval of 0.12 to 2.50. The Cochran Q p-value was 0.677 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 14 Impact of catheter aspiration devices versus control on in-hospital myocardial infarction

Cochran Q: P = 1.000

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on in-hospital myocardial infarction. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.66. The second trial by Sardella and colleagues in 2009 was excluded from the analysis because no events occurred in the groups compared. The third trial by Ikari and colleagues in 2008 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.67. The fourth trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no events occurred in either the treatment or control group and therefore a relative risk could not be calculated. The combined effect of the two trials showed a relative risk of 0.32 with a 95 percent confidence interval of 0.03 to 3.06. The Cochran Q p-value was 1.000, the I-squared value and Egger's p-value could not be calculated because of too few studies.

Figure 15 Impact of catheter aspiration devices versus control on ≤30 day myocardial infarction

Cochran Q: P = 0.816

I^2^: 0%

Egger: P = 0.809

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on ≤30-day myocardial infarction versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.66. The second trial by Sardella and colleagues in 2009 was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or control groups and therefore a relative risk could not be calculated. The third trial by Chevalier and colleagues in 2008 provided a relative risk of 2.15 with 95 percent confidence interval of 0.28 to 16.30. The fourth trial by Ikari and colleagues, also in 2008 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.00 to 3.67. The fifth trial by Svilaas and colleagues also in 2008 provided a relative risk of 0.40 with 95 percent confidence interval of 0.13 to 1.20. The sixth trial by Kaltoft and colleagues in 2006, provided a relative risk of 0.33 with 95 percent confidence interval of 0.00 to 3.78. The seventh trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or control groups and therefore a relative risk could not be calculated. The eighth trial by Burzotta and colleagues also in 2006, provided a relative risk of 1.00 with 95 percent confidence interval of 0.18 to 5.50. The combined effect of the six trials showed a relative risk of 0.55 with a 95 percent confidence interval of 0.24 to 1.25. The Cochran Q p-value was 0.816, the I-squared value was 0 percent and the Egger's p-value was 0.809.

Figure 16 Impact of catheter aspiration devices versus control on 30-day myocardial infarction

Cochran Q: P = 0.578

I^2^: 0%

Egger: P = 0.499

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 30-day myocardial infarction. The first trial by Sardella and colleagues in 2009 was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The second trial by Chevalier and colleagues in 2008 provided a relative risk of 2.15 with a 95 percent confidence interval of 0.28 to 16.30. The third trial by Svilaas and colleagues in 2008 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.13 to 1.20. The fourth trial by Kaltoft and colleagues in 2006 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.78. The fifth trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.18 to 5.50. The combined effect of the four trials showed a relative risk of 0.60 with a 95 percent confidence interval of 0.25 to 1.45. The Cochran Q p-value was 0.578, the I-squared value was zero percent and the Egger's p-value was 0.499.

Figure 17 Impact of catheter aspiration devices versus control on 180-day myocardial infarction

Cochran Q: P = 0.721

I^2^: 0%

Egger: P = 0.708

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on 180-day myocardial infarction versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.05 to 2.19. The second trial by Liistro and colleagues in 2009 provided a relative risk of 1.02 with 95 percent confidence interval of 0.24 to 4.26. The third trial by Sardella and colleagues also in 2009, was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or control groups and therefore a relative risk could not be calculated. The fourth trial by Ikari and colleagues in 2008 provided a relative risk of 0.31 with a 95 percent confidence interval of 0.00 to 3.55. The fifth trial by De Luca and colleagues in 2006, provided a relative risk of 3.25 with 95 percent confidence interval of 0.29 to infinity. The sixth trial by Silva-Orrego and colleagues in 2006, provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.60. The combined effect of the five trials showed a relative risk of 0.70 with a 95 percent confidence interval of 0.24 to 1.99. The Cochran Q p-value was 0.721, the I-squared value was 0 percent and the Egger's p-value was 0.708.

Figure 18 Impact of catheter aspiration devices versus control on 365-day myocardial infarction

Cochran Q: P = 0.782

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 365-day myocardial infarction. The first trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The second trial by Svilaas and colleagues provided a relative risk of 0.52 with a 95 percent confidence interval of 0.27 to 1.03. The combined effect of the two trials showed a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.00. The Cochran Q p-value was 0.782 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 19 Impact of mechanical thrombectomy devices versus control on ≤ 30-day myocardial infarction

Cochran Q: P = 0.769

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on ≤30 day myocardial infarction. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.64 with 95 percent confidence interval of 0.13 to 3.17. The second trial by Ali and colleagues in 2006 was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 0.34 with a 95 percent confidence interval of 0.05 to 2.31. The fourth trial by Antoniucci and colleagues in 2004 was excluded from the meta-analysis because no myocardial infarctions occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The fifth trial by Napodano and colleagues in 2003 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.18 to 5.50. The combined effect of the three trials showed a relative risk of 0.63 with a 95 percent confidence interval of 0.21 to 1.96. The Cochran Q p-value was 0.769, the I-squared value was zero percent and there were too few strata to calculate the Egger's p-value.

Figure 20 Impact of mechanical thrombectomy devices versus control on 180-day myocardial infarction

Cochran Q: P = 0.847

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on 180- day myocardial infarction. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.64 with 95 percent confidence interval of 0.13 to 3.19. The second trial by Lefevre and colleagues in 2005 provided a relative risk of 0.51 with a 95 percent confidence interval of 0.11 to 2.31. The combined effect of the two trials showed a relative risk of 0.57 with a 95 percent confidence interval of 0.17 to 1.92. The Cochran Q p-value was 0.847 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 21 Impact of distal filter embolic protection devices versus control on ≤30-day myocardial infarction

Cochran Q: P = 0.146

I^2^: 44.3 percent

Egger: 0.128

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on in-hospital mortality versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.23 to 4.08. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The third trial by Ikari and colleagues in 2008 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.16. The fourth trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no deaths occurred in either the treatment or control group and therefore a relative risk could not be calculated. The combined effect of the three trials showed a relative risk of 0.81 with a 95 percent confidence interval of 0.23 to 2.86. The Cochran Q p-value was 0.832, the I-squared value was zero percent and the Egger's p-value could not be evaluated because of too few strata.

Figure 22 Impact of distal balloon embolic protection devices versus control on ≤30-day myocardial infarction

Cochran Q: P = 0.670

I^2^: 0%

Egger: P = 0.517

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on ≤30 day myocardial infarction. The first trial by Tahk and colleagues in 2008 provided a relative risk of 2.89 with a 95 percent confidence interval of 0.25 to infinity. The second trial by Matsuo and colleagues in 2007 provided a relative risk of 2.78 with a 95 percent confidence interval of 0.24 to infinity. The third trial by Muramatsu and colleagues in 2007 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.00 to 3.71. The fourth trial by Stone and colleagues in 2005 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.24 to 2.09. The combined effect of the four trials showed a relative risk of 0.85 with a 95 percent confidence interval of 0.32 to 2.23. The Cochran Q p-value was 0.670, the I-squared value was zero percent and the Egger's p-value was 0.517.

Figure 23 Impact of distal balloon embolic protection devices versus control on 180-day myocardial infarction

Cochran Q: P = 0.877

I^2^: 0%

Egger: P = 0.820

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on ≤30 day mortality versus control. The first trial by Ito and colleagues in 2010 provided a relative risk of 0.30 with 95 percent confidence interval of 0.00 to 3.30. The second trial by Haeck and colleagues in 2009 provided a relative risk of 1.01 with 95 percent confidence interval of 0.18 to 5.69. The third trial by Kelbaeck and colleagues in 2008 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.40 to 2.56. The fourth trial by Tahk and colleagues in 2008 provided a relative risk of 0.19 with 95 percent confidence interval of 0.00 to 1.81.The fifth trial by Cura and colleagues in 2007 provided a relative risk of 1.00 with 95 percent confidence interval of 0.28 to 3.53. The sixth trial by Guetta and colleagues also in 2007 provided a relative risk of 4.81 with a 95 percent confidence interval of 0.51 to infinity. The seventh trial by Muramatsu and colleagues also in 2007, provided a relative risk of 0.69 with a 95 percent confidence interval of 0.24 to 2.03. The eighth trial by Stone and colleagues in 2005 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.24 to 2.09. The ninth trial by Lefevre and colleagues in 2004, provided a relative risk of 0.88 with 95 percent confidence interval of 0.09 to 8.17. The combined effect of the nine trials showed a relative risk of 0.84 with a 95 percent confidence interval of 0.50 to 1.39. The Cochran Q p-value was 0.931, the I-squared value was 0 percent and the Egger's p-value was 0.794.

Figure 24 Impact of embolic protection devices combined versus control on ≤30 day myocardial infarction

Cochran Q: P = 0.542

I^2^: 0%

Egger: P = 0.982

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on ≤30 day myocardial infarction versus control. The first trial by Ito and colleagues in 2010 was excluded from the analysis because no events occurred in either of the two groups. The second trial by Haeck and colleagues in 2009 provided a relative risk of 0.68 with 95 percent confidence interval of 0.14 to 3.34. The third trial by Kelbaeck and colleagues in 2008 provided a relative risk of 5.03 with a 95 percent confidence interval of 0.79 to 32.40. The fourth trial by Tahk and colleagues in 2008 provided a relative risk of 2.89 with 95 percent confidence interval of 0.25 to infinity. The fifth trial by Cura and colleagues in 2007 provided a relative risk of 0.09 with 95 percent confidence interval of 0.00 to 0.74. The sixth trial by Guetta and colleagues also in 2007 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.63. The seventh trial by Matsuo and colleagues also in 2007, provided a relative risk of 2.78 with 95 percent confidence interval of 0.24 to infinity. The eighth trial by Muramatsu and colleagues, also in 2007 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.71. The ninth trial by Stone and colleagues in 2005 provided a relative risk of 0.71 with 95 percent confidence interval of 0.24 to 2.09. The tenth trial by Lefevre and colleagues in 2004 provided a relative risk of 0.88 with a 95 percent confidence interval of 0.09 to 8.17. The combined effect of the nine trials showed a relative risk of 0.83 with a 95 percent confidence interval of 0.41 to 1.69. The Cochran Q p-value was 0.542, the I-squared value was 0 percent and the Egger's p-value was 0.982.

Figure 25 Impact of embolic protection devices combined versus control on 180-day myocardial infarction

Cochran Q: P = 0.756

I^2^: 0%

Egger: P = 0.880

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on 180-day myocardial infarction versus control. The first trial by Haeck and colleagues in 2009 provided a relative risk of 1.01 with 95 percent confidence interval of 0.24 to 4.33. The second trial by Tahk and colleagues in 2008 provided a relative risk of 0.96 with 95 percent confidence interval of 0.10 to 9.09. The third trial by Cura and colleagues in 2007 provided a relative risk of 0.09 with a 95 percent confidence interval of 0.00 to 0.74. The fourth trial by Hahn and colleagues in 2007 provided a relative risk of 0.35 with 95 percent confidence interval of 0.00 to 3.88. The fifth trial by Matsuo and colleagues also in 2007, provided a relative risk of 2.78 with 95 percent confidence interval of 0.24 to infinity. The sixth trial by Muramatsu and colleagues, also in 2007 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.71. The seventh trial by Stone and colleagues in 2005 provided a relative risk of 0.64 with 95 percent confidence interval of 0.24 to 1.70. The combined effect of the seven trials showed a relative risk of 0.65 with a 95 percent confidence interval of 0.31 to 1.33. The Cochran Q p-value was 0.756, the I-squared value was 0 percent and the Egger's p-value was 0.880.

Figure 26 Impact of catheter aspiration devices versus control on 30-day stroke

Cochran Q: P = 0.647

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 30-day stroke. The first trial by Chevalier and colleagues in 2008 provided a relative risk of 5.37 with a 95 percent confidence interval of 0.57 to infinity. The second trial by Kaltoft and colleagues in 2006 provided a relative risk of 4.95 with a 95 percent confidence interval of 0.52 to infinity. The third trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.42. The combined effect of the three trials showed a relative risk of 2.77 with a 95 percent confidence interval of 0.51 to 14.98. The Cochran Q p-value was 0.647, the I-squared value was zero percent and there were too few strata to calculate the Egger's p-value.

Figure 27 Impact of mechanical thrombectomy devices versus control on ≤ 30-day stroke

Cochran Q: P = 0.641

I^2^: 0%

Egger: P = 0.870

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on ≤30 day stroke. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.67. The second trial by Ali and colleagues in 2006 provided a relative risk of 2.00 with a 95 percent confidence interval of 0.43 to 9.28. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 5.05 with a 95 percent confidence interval of 0.53 to infinity. The fourth trial by Antoniucci and colleagues in 2004 provided a relative risk of 3.00 with a 95 percent confidence interval of 0.26 to infinity. The fifth trial by Napodano and colleagues in 2003 was excluded from the meta-analysis because no strokes occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The combined effect of the four trials showed a relative risk of 1.89 with a 95 percent confidence interval of 0.55 to 6.48. The Cochran Q p-value was 0.641, the I-squared value was zero percent and the Egger's p-value was 0.870.

Figure 28 Impact of mechanical thrombectomy devices versus control on 180-day stroke

Cochran Q: P = 0.424

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on 180-day stroke. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.10 to 9.21. The second trial by Lefevre and colleagues in 2005 provided a relative risk of 5.05 with a 95 percent confidence interval of 0.53 to infinity. The combined effect of the two trials showed a relative risk of 2.05 with a 95 percent confidence interval of 0.27 to 15.78. The Cochran Q p-value was 0.424, and there were too few strata to calculate the I-squared value and the Egger's p-value.

Figure 29 Impact of embolic protection devices combined versus control on ≤30 day stroke

Cochran Q: P = 0.277

I^2^: 22.1%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal filter embolic protection devices versus control on ≤30-day stroke. The first trial by Haeck and colleagues in 2009 provided a relative risk of 0.34 with a 95 percent confidence interval of 0.00 to 3.87. The second trial by Kelbaek and colleagues in 2008 provided a relative risk of 1.51 with a 95 percent confidence interval of 0.30 to 7.52. The third trial by Stone and colleagues in 2005 provided a relative risk of 0.11 with a 95 percent confidence interval of 0.00 to 0.94. The combined effect of the three trials showed a relative risk of 0.56 with a 95 percent confidence interval of 0.11 to 2.84. The Cochran Q p-value was 0.277, the I-squared value was 22.1 percent and there were too few strata to calculate the Egger's p-value.

Figure 30 Impact of embolic protection devices combined versus control on 180 day stroke

Cochran Q: P = 0.624

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on in-hospital mortality versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.23 to 4.08. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The third trial by Ikari and colleagues in 2008 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.16. The fourth trial by Silva-Orrego and colleagues in 2006 was excluded from the meta-analysis because no deaths occurred in either the treatment or control group and therefore a relative risk could not be calculated. The combined effect of the three trials showed a relative risk of 0.81 with a 95 percent confidence interval of 0.23 to 2.86. The Cochran Q p-value was 0.832, the I-squared value was zero percent and the Egger's p-value could not be evaluated because of too few strata.

Figure 31 Impact of catheter aspiration devices versus control on 180-day target revascularization

Cochran Q: P = 0.759

I^2^: 0%

Egger: P = 0.444

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on 180-day target revascularization versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.66. The second trial by Liistro and colleagues in 2009 provided a relative risk of 1.02 with 95 percent confidence interval of 0.29 to 3.56. The third trial by Sardella and colleagues also in 2009, provided a relative risk of 0.09 with 95 percent confidence interval of 0.00 to 0.74. The fourth trial by Chao and colleagues in 2008 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.20 to 2.82. The fifth trial by Ikari and colleagues also in 2008, provided a relative risk of 0.60 with 95 percent confidence interval of 0.36 to 1.00. The sixth trial by Silva-Orrego and colleagues in 2006, provided a relative risk of 0.47 with 95 percent confidence interval of 0.06 to 3.54. The combined effect of the six trials showed a relative risk of 0.61 with a 95 percent confidence interval of 0.39 to 0.94. The Cochran Q p-value was 0.759, the I-squared value was 0 percent and the Egger's p-value was 0.444

Figure 32 Impact of catheter aspiration devices versus control on ≤ 30 day target revascularization

Cochran Q: P = 0.832

I^2^: 0%

Egger: P = 0.254

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on ≤30 day target revascularization versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 1.92 with 95 percent confidence interval of 0.26 to 14.53. The second trial by Sardella and colleagues in 2009 was excluded from the meta-analysis because no targert revascularizations occurred in either the treatment or control groups and therefore a relative risk could not be calculated. The third trial by Chevalier and colleagues in 2009, provided a relative risk of 2.15 with 95 percent confidence interval of 0.28 to 16.30. The fourth trial by Ikari and colleagues in 2008 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.00 to 3.67. The fifth trial by Svilaas and colleagues also in 2008, provided a relative risk of 0.78 with 95 percent confidence interval of 0.46 to 1.30. The sixth trial by Silva-Orrego and colleagues in 2006, provided a relative risk of 3.00 with 95 percent confidence interval of 0.26 to infinity. The seventh trial by Burzotta and colleagues in 2005, provided a relative risk of 1.00 with 95 percent confidence interval of 0.11 to 9.42. The combined effect of the seven trials showed a relative risk of 0.85 with a 95 percent confidence interval of 0.53 to 1.38. The Cochran Q p-value was 0.832, the I-squared value was 0 percent and the Egger's p-value was 0.254.

Figure 33 Impact of catheter aspiration devices versus control on 30-day target revascularization

Cochran Q: P = 0.709

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 30-day target revascularization. The first trial by Sardella and colleagues in 2009 was excluded from the meta-analysis because no target revascularizations occurred in either the treatment or control group and therefore a relative risk could not be calculated. The second trial by Chevalier and colleagues in 2008 provided a relative risk of 2.15 with a 95 percent confidence interval of 0.28 to 16.30. The third trial by Svilaas and colleagues, also in 2008, provided a relative risk of 0.78 with a 95 percent confidence interval of 0.46 to 1.30. The fourth trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.42. The combined effect of the three trials showed a relative risk of 0.82 with a 95 percent confidence interval of 0.50 to 1.35. The Cochran Q p-value was 0.709, the I-squared value was zero percent and there were too few strata to calculate the Egger's p-value.

Figure 34 Impact of catheter aspiration devices versus control on 365-day target revascularization

Cochran Q: P = 0.886

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 365-day target revascularization. The first trial by Sardella and colleagues in 2009 provided a relative risk of 0.79 with a 95 percent confidence interval of 0.24 to 2.64. The second trial by Svilaas and colleagues in 2008 provided a relative risk of 0.87 with a 95 percent confidence interval of 0.63 to 1.20. The combined effect of the two trials showed a relative risk of 0.87 with a 95 percent confidence interval of 0.63 to 1.19. The Cochran Q p-value was 0.886, and there were too few strata to calculate the I-squared value and the Egger's p-value.

Figure 35 Impact of catheter aspiration devices versus control on in-hospital target revascularization

Cochran Q: P = 0.575

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on in-hospital target revascularization versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 1.92 with 95 percent confidence interval of 0.26 to 14.53. The second trial by Ikari and colleagues in 2008 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.00 to 3.67. The third trial by Silva-Orrego and colleagues in 2006, provided a relative risk of 3.00 with 95 percent confidence interval of 0.26 to infinity. The combined effect of the three trials showed a relative risk of 1.35 with a 95 percent confidence interval of 0.26 to 6.94. The Cochran Q p-value was 0.575, the I-squared value was 0 percent and the Egger's p-value could not be evaluated because of too few strata.

Figure 36 Impact of mechanical thrombectomy devices versus control on ≤ 30-day target revascularization

Cochran Q: P = 0.072

I^2^: 62%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on ≤30 day target revascularization. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.32 with 95 percent confidence interval of 0.07 to 1.37. The second trial by Ali and colleagues in 2006 provided a relative risk of 5.00 with a 95 percent confidence interval of 0.78 to 32.16. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 5.05 with a 95 percent confidence interval of 0.53 to infinity. The fourth trial by Antoniucci and colleagues in 2004 and the fifth trial by Napodano and colleagues in 2003 were excluded from the meta-analysis because no target revascularizations occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The combined effect of the three trials showed a relative risk of 1.62 with a 95 percent confidence interval of 0.21 to 12.55. The Cochran Q p-value was 0.072, the I-squared value was 62 percent and there were too few strata to calculate the Egger's p-value.

Figure 37 Impact of mechanical thrombectomy devices versus control on 180-day target revascularization

Cochran Q: P = 0.885

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on 180-day target revascularization. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.54 with 95 percent confidence interval of 0.31 to 0.93. The second trial by Lefevre and colleagues in 2005 provided a relative risk of 0.61 with a 95 percent confidence interval of 0.16 to 2.44. The combined effect of the two trials showed a relative risk of 0.55 with a 95 percent confidence interval of 0.33 to 0.92. The Cochran Q p-value was 0.885 and, there were too few strata to calculate the I-squared value and the Egger's p-value.

Figure 38 Impact of distal balloon embolic protection devices versus control on ≤30-day target revascularization

Cochran Q: P = 0.600

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on ≤30-day target revascularization. The first trial by Tahk and colleagues in 2008 provided a relative risk of 2.89 with a 95 percent confidence interval of 0.25 to infinity. The second trial by Muramatsu and colleagues in 2007 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.00 to 3.71. The third trial by Stone and colleagues in 2005 provided a relative risk of 1.49 with a 95 percent confidence interval of 0.56 to 3.96. The combined effect of the three trials showed a relative risk of 1.38 with a 95 percent confidence interval of 0.55 to 3.50. The Cochran Q p-value was 0.600, the I-squared value was zero percent and there were too few strata to calculate the Egger's p-value.

Figure 39 Impact of distal balloon embolic protection devices versus control on 180-day target revascularization

Cochran Q: P = 0.600

I^2^: 0%

Egger: 0.369

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on 180-day target revascularization. The first trial by Tahk and colleagues in 2008 provided a relative risk of 1.44 with a 95 percent confidence interval of 0.30 to 7.04. The second trial by Hahn and colleagues in 2007 provided a relative risk of 0.21 with a 95 percent confidence interval of 0.00 to 1.89. The third trial by Matsuo and colleagues, also in 2007, provided a relative risk of 0.51 with a 95 percent confidence interval of 0.19 to 1.39. The fourth trial by Muramatsu and colleagues, also in 2007, provided a relative risk of 1.03 with a 95 percent confidence interval of 0.55 to 1.95. The fifth trial by Stone and colleagues in 2005 provided a relative risk of 1.11 with a 95 percent confidence interval of 0.55 to 2.24. The combined effect of the five trials showed a relative risk of 0.93 with a 95 percent confidence interval of 0.61 to 1.42. The Cochran Q p-value was 0.600, the I-squared value was zero percent and the Egger's p-value was 0.369.

Figure 40 Impact of embolic protection devices combined versus control on 180-day target revascularization

Cochran Q: P = 0.799

I^2^: 0%

Egger: P = 0.268

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on 180 day target revascularization versus control. The first trial by Haeck and colleagues in 2009 provided a relative risk of 0.71 with 95 percent confidence interval of 0.29 to 1.75. The second trial by Tahk and colleagues in 2008 provided a relative risk of 1.44 with 95 percent confidence interval of 0.30 to 7.04. The third trial by Cura and colleagues in 2007, provided a relative risk of 1.00 with 95 percent confidence interval of 0.35 to 2.82. The fourth trial by Hahn and colleagues also in 2007, provided a relative risk of 0.21 with a 95 percent confidence interval of 0.00 to 1.89. The fifth trial by Matsuo and colleagues also in 2007, provided a relative risk of 0.51 with 95 percent confidence interval of 0.19 to 1.39. The sixth trial by Muramatsu and colleagues also in 2007, provided a relative risk of 1.03 with 95 percent confidence interval of 0.55 to 1.95. The seventh trial by Stone and colleagues in 2005, provided a relative risk of 1.11 with 95 percent confidence interval of 0.55 to 2.24. The combined effect of the seven trials showed a relative risk of 0.90 with a 95 percent confidence interval of 0.63 to 1.30. The Cochran Q p-value was 0.799, the I-squared value was 0 percent and the Egger's p-value was 0.268.

Figure 41 Impact of embolic protection devices combined versus control on ≤30 day target revascularization

Cochran Q: P = 0.417

I^2^: 0%

Egger: P = 0.900

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices on ≤30 day target revascularization versus control. The first trial by Ito and colleagues in 2010 was excluded from the meta-analysis because no events occurred in either of the groups and therefore a relative risk could not be calculated. The second trial by Haeck and colleagues in 2009 provided a relative risk of 0.51 with 95 percent confidence interval of 0.14 to 1.81. The third tiral by Kelbaeck and colleagues in 2008 provided a relative risk of 3.02 with 95 percent confidence interval of 0.70 to 13.01. The fourth trial by Tahk and colleagues also in 2008 provided a relative risk of 2.89 with 95 percent confidence interval of 0.25 to infinity. The fifth trial by Muramatsu and colleagues in 2007, provided a relative risk of 0.32 with 95 percent confidence interval of 0.00 to 3.71. The sixth trial by Stone and colleagues in 2005, provided a relative risk of 1.49 with 95 percent confidence interval of 0.56 to 3.96. The combined effect of the six trials showed a relative risk of 1.24 with a 95 percent confidence interval of 0.62 to 2.48. The Cochran Q p-value was 0.417, the I-squared value was 0 percent and the Egger's p-value was 0.900.

Figure 42 Impact of catheter aspiration devices versus control on in-hospital MACE

Cochran Q: P = 0.713

I^2^: 0%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on in-hospital MACE versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.31 to 3.02. The second trial by Sardella and colleagues in 2009 provided a relative risk of 1.98 with a 95 percent confidence interval of 0.26 to 14.95. The third trial by Ikari and colleagues in 2008, provided a relative risk of 0.48 with 95 percent confidence interval of 0.06 to 3.64. The combined effect of the three trials showed a relative risk of 0.97 with a 95 percent confidence interval of 0.36 to 2.58. The Cochran Q p-value was 0.713, the I-squared value was 0 percent and the Egger's p-value could not be evaluated because of too few strata.

Figure 43 Impact of catheter aspiration devices versus control on ≤ 30 day MACE

Cochran Q: P = 0.948

I^2^: 0%

Egger: P = 0.739

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on ≤ 30 day MACE versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.31 to 3.02. The second trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.00 to 3.76. The third trial by Chevalier and colleagues in 2008, provided a relative risk of 1.25 with 95 percent confidence interval of 0.45 to 3.47. The fourth trial by Ikari and colleagues also in 2008, provided a relative risk of 0.48 with a 95 percent confidence interval of 0.06 to 3.64. The fifth trial by Svilaas and colleagues in 2008, provided a relative risk of 0.72 with 95 percent confidence interval of 0.48 to 1.09. The sixth trial by Kaltoft and colleagues in 2006, provided a relative risk of 0.99 with a 95 percent confidence interval of 0.18 to 5.54. The seventh trial by Burzotta and colleagues in 2005, provided a relative risk of 1.00 with 95 percent confidence interval of 0.33 to 3.05. The combined effect of the seven trials showed a relative risk of 0.80 with a 95 percent confidence interval of 0.57 to 1.12. The Cochran Q p-value was 0.948, the I-squared value was 0 percent and the Egger's p-value was 0.739.

Figure 44 Impact of catheter aspiration devices versus control on 30-day MACE

Cochran Q: P = 0.844

I^2^: 0%

Egger: P = 0.61

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 30 day MACE. The first trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with 95 percent confidence interval of 0.00 to 3.76. The second trial by Chevalier and colleagues in 2008 provided a relative risk of 1.25 with a 95 percent confidence interval of 0.45 to 3.47. The third trial by Svilaas and colleagues, also in 2008, provided a relative risk of 0.72 with a 95 percent confidence interval of 0.48 to 1.09. The fourth trial by Kaltoft and colleagues in 2006 provided a relative risk of 0.99 with a 95 percent confidence interval 0.18 to 5.54. The fifth trial by Burzotta and colleagues in 2005 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.33 to 3.05. The combined effect of the five trials showed a relative risk of 0.79 with a 95 percent confidence interval of 0.56 to 1.13. The Cochran Q p-value was 0.844, the I-squared value was zero percent and the Egger's p-value was 0.619

Figure 45 Impact of catheter aspiration devices versus control on 365-day MACE

Cochran Q: 0.111

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices versus control on 365-day MACE. The first trial by Sardella and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.12 to 0.93. The second trial by Svilaas and colleagues in 2008 provided a relative risk of 0.82 with a 95 percent confidence interval of 0.64 to 1.05. The combined effect of the two trials showed a relative risk of 0.61 with a 95 percent confidence interval of 0.26 to 1.41. The Cochran Q p-value was 0.111 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 46 Impact of catheter aspiration devices versus control on 180-day MACE

Cochran Q: P = 0.785

I^2^: 0%

Egger: P = 0.733

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of catheter aspiration devices on 180-day MACE versus control. The first trial by Dudek and colleagues in 2010 provided a relative risk of 0.80 with 95 percent confidence interval of 0.27 to 2.40. The second trial by Liistro and colleagues in 2009 provided a relative risk of 1.16 with a 95 percent confidence interval of 0.47 to 2.91. The third trial by Sardella and colleagues in 2009, provided a relative risk of 0.44 with 95 percent confidence interval of 0.15 to 1.29. The fourth trial by Chao and colleagues in 2008, provided a relative risk of 0.50 with a 95 percent confidence interval of 0.19 to 1.26. The fifth trial by Ikari and colleagues also in 2008, provided a relative risk of 0.62 with 95 percent confidence interval of 0.38 to 1.01. The sixth trial by De Luca and colleagues in 2006, provided a relative risk of 0.81 with a 95 percent confidence interval of 0.21 to 3.05. The combined effect of the six trials showed a relative risk of 0.66 with a 95 percent confidence interval of 0.47 to 0.94. The Cochran Q p-value was 0.785, the I-squared value was 0 percent and the Egger's p-value was 0.733.

Figure 47 Impact of mechanical thrombectomy devices versus control on ≤ 30-day MACE

Cochran Q: P = 0.006

I^2^: 80.4%

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on ≤30 day MACE. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.45 with 95 percent confidence interval of 0.20 to 1.00. The second trial by Ali and colleagues in 2006 provided a relative risk of 4.00 with a 95 percent confidence interval of 1.43 to 11.29. The third trial by Lefevre and colleagues in 2005 provided a relative risk of 1.30 with a 95 percent confidence interval of 0.52 to 3.25. The fourth trial by Antoniucci and colleagues in 2004 was excluded from the meta-analysis because no MACE occurred in either the treatment or the control group and therefore a relative risk could not be calculated. The combined effect of the three trials showed a relative risk of 1.28 with a 95 percent confidence interval of 0.37 to 4.38. The Cochran Q p-value was 0.006, the I-squared value was 80.4 percent and there were too few strata to calculate the Egger's p-value.

Figure 48 Impact of mechanical thrombectomy devices versus control on 180-day MACE

Cochran Q: P = 0.187

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of mechanical thrombectomy devices versus control on 180- day MACE. The first trial by Migliorini and colleagues in 2010 provided a relative risk of 0.57 with 95 percent confidence interval of 0.37 to 0.88. The second trial by Lefevre and colleagues in 2005 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.50 to 2.04. The combined effect of the two trials showed a relative risk of 0.71 with a 95 percent confidence interval of 0.41 to 1.20. The Cochran Q p-value was 0.187 and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 49 Impact of distal filter embolic protection devices versus control on ≤30 day MACE

Cochran Q: P = 0.664

I^2^: 0%

Egger: P = 0.449

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact distal filter embolic protection devices on ≤30-day MACE versus control. The first trial by Ito and colleagues in 2010 provided a relative risk of 0.30 with 95 percent confidence interval of 0.00 to 3.30. The second trial by Kelbaeck and colleagues in 2008 provided a relative risk of 1.71 with a 95 percent confidence interval of 0.81 to 3.62. The third trial by Cura and colleagues in 2007, provided a relative risk of 1.00 with 95 percent confidence interval of 0.45 to 2.21. The fourth trial by Guetta and colleagues in 2007, provided a relative risk of 2.88 with a 95 percent confidence interval of 0.43 to 19.79. The fifth trial by Lefevre and colleagues in 2004, provided a relative risk of 0.88 with 95 percent confidence interval of 0.16 to 4.74. The combined effect of the five trials showed a relative risk of 1.29 with a 95 percent confidence interval of 0.77 to 2.15. The Cochran Q p-value was 0.664, the I-squared value was 0 percent and the Egger's p-value was 0.449.

Figure 50 Impact of distal filter embolic protection devices versus control on 180-day MACE events

Cochran Q: P = 0.550

I^2^: Too few strata

Egger: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal filter embolic protection devices versus control on 180-day MACE. The first trial by Kelbaek and colleagues in 2008 provided a relative risk of 1.23 with a 95 percent confidence interval of 0.68 to 2.23. The second trial by Cura and colleagues in 2007 provided a relative risk of 0.91 with a 95 percent confidence interval of 0.42 to 1.96. The combined effect of the two trials showed a relative risk of 1.10 with a 95 percent confidence interval of 0.68 to 1.78. The Cochran Q p-value was 0.550, and there were too few strata to calculate the I-squared value or the Egger's p-value.

Figure 51 Impact of distal balloon embolic protection devices versus control on ≤30-day MACE

Cochran Q: P = 0.919

I^2^: 0%

Egger: P = 0.758

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on ≤30 day MACE. The first trial by Tahk and colleagues in 2008 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.17 to 5.32. The second trial by Matsuo and colleagues in 2007 provided a relative risk of 0.93 with a 95 percent confidence interval of 0.22 to 3.91. The third trial by Muramatsu and colleagues, also in 2007, provided a relative risk of 0.54 with a 95 percent confidence interval of 0.19 to 1.50. The fourth trial by Zhou and colleagues, also in 2007, was excluded from the meta-analysis because no MACE occurred in either the treatment or control group and therefore a relative risk could not be calculated. The fifth trial by Stone and colleagues in 2005 provided a relative risk of 0.77 with a 95 percent confidence interval of 0.40 to 1.50. The combined effect of the four trials showed a relative risk of 0.74 with a 95 percent confidence interval of 0.44 to 1.23. The Cochran Q p-value was 0.919, the I-squared value was zero percent and the Egger's p-value was 0.758.

Figure 52 Impact of distal balloon embolic protection devices combined versus control on 180- day MACE

Cochran Q: P = 0.685

I^2^: 0%

Egger: P = 0.032

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of distal balloon embolic protection devices versus control on 180-day MACE. The first trial by Tahk and colleagues in 2008 provided a relative risk of 0.77 with a 95 percent confidence interval of 0.23 to 2.52. The second trial by Hahn and colleagues in 2007 provided a relative risk of 0.12 with a 95 percent confidence interval of 0.00 to 0.91. The third trial by Matsuo and colleagues, also in 2007, provided a relative risk of 0.77 with a 95 percent confidence interval of 0.36 to 1.65. The fourth trial by Muramatsu and colleagues, also in 2007, provided a relative risk of 0.97 with a 95 percent confidence interval of 0.60 to 1.56. The fifth trial by Stone and colleagues in 2005 provided a relative risk of 0.89 with a 95 percent confidence interval of 0.53 to 1.49. The combined effect of the five trials showed a relative risk of 0.87 with a 95 percent confidence interval of 0.64 to 1.19. The Cochran Q p-value was 0.685, the I-squared value was zero percent and the Egger's p-value was 0.032.

Figure 53 Impact of embolic protection devices combined versus control on ≤30 day MACE

Cochran Q: P = 0.744

I^2^: 0%

Egger: P = 0.821

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact embolic protection devices combined on ≤30-day MACE versus control. The first trial by Ito and colleagues in 2010 provided a relative risk of 0.30 with 95 percent confidence interval of 0.00 to 3.30. The second trial by Haeck and colleagues in 2009 provided a relative risk of 0.61 with 95 percent confidence interval of 0.23 to 1.57. The third trial by Kelbaeck and colleagues in 2008 provided a relative risk of 1.71 with a 95 percent confidence interval of 0.81 to 3.62. The fourth trial by Tahk and colleagues also in 2008, provided a realtive risk of 0.96 with 95 percent confidence interval of 0.17 to 5.32. The fifth trial by Cura and colleagues in 2007, provided a relative risk of 1.00 with 95 percent confidence interval of 0.45 to 2.21. The sixth trial by Guetta and colleagues in 2007, provided a relative risk of 2.88 with a 95 percent confidence interval of 0.43 to 19.79. The seventh trial by Matsuo and colleagues also in 2007, provided a relative risk of 0.93 with 95 percent confidence interval of 0.22 to 3.91. The eighth trial by Muramatsu and colleagues also in 2007, provided a relative risk of 0.54 with 95 percent confidence interval of 0.19 to 1.50. The ninth trial by Zhou and colleagues also in 2007 was excluded from the meta-analysis because no events occurred in either of the groups and therefore a relative risk could not be calculated. The tenth trial by Stone and colleagues in 2005 provided a relative risk of 0.77 with 95 percent confidence of 0.40 to 1.50. The eleventh trial by Lefevre and colleagues in 2004, provided a relative risk of 0.88 with 95 percent confidence interval of 0.16 to 4.74. The combined effect of the ten trials showed a relative risk of 0.92 with a 95 percent confidence interval of 0.66 to 1.30. The Cochran Q p-value was 0.774, the I-squared value was 0 percent and the Egger's p-value was 0.821.

Figure 54 Impact of embolic protection devices combined versus control on 180-day MACE

Cochran Q: P = 0.828

I^2^: 0%

Egger: P = 0.029

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of embolic protection devices combined versus control on 180-day MACE. The first trial by Haeck and colleagues in 2009 provided a relative risk of 0.74 with 95 percent confidence interval of 0.36 to 1.54. The second trial by Kelbaek and colleagues in 2008 provided a relative risk of 1.23 with a 95 percent confidence interval of 0.68 to 2.23. The third trial by Tahk and colleagues in 2008 provided a relative risk of 0.77 with 95 percent confidence interval of 0.23 to 2.52. The fourth trial by Cura and colleagues in 2007 provided a relative risk of 0.91 with a 95 percent confidence interval of 0.42 to 1.96. The fifth trial by Hahn and colleagues in 2007, provided a relative risk of 0.12 with 95 percent confidence interval of 0.00 to 0.91. The sixth trial by Matsuo and colleagues in 2007 provided a relative risk of 0.77 with a 95 percent confidence interval of 0.36 to 1.65. The seventh trial by Muramatsu and colleagues in 2007 provided a relative risk of 0.97 with a 95 percent confidence interal of 0.60 to 1.56. The eighth trial by Stone and colleagues in 2005 provided a relative risk of 0.89 with 95 percent confidence interval of 0.53 to 1.49. The combined effect of the eight trials showed a relative risk of 0.91 with a 95 percent confidence interval of 0.71 to 1.16. The Cochran Q p-value was 0.828, the I-squared value was 0 percent and the Egger's p-value was 0.029.