# Applicability of Individual Studies and of the Body of Evidence

Table 221 Evaluation of applicability for individual randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Dudek, 2010 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Intervention, Outcomes, Setting | Younger population (58 y) High male to female ratio (79-81%) Only patients undergoing primary PCI Short duration of followup (180 d) Diver CE device no longer available Adverse outcomes not reported Small sample size (N= 196) Use of ITT analysis not reported Conducted in Europe
Liistro, 2009 | Study Designation: Efficacy study Composite Score: 4 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcomes Used intention to treat analysis | Population, Setting | High male to female ratio (77-78%) Only patients undergoing primary PCI Short duration of followup (180 d) Small sample size (N =111) Conducted in Europe
Lipiecki, 2009 | Study Designation: Efficacy study Composite Score: 1 of 7 | Enrolled primary care population | Population, Outcomes, Setting | Younger population (59 y) Final health outcomes not reported Short duration of followup (7 d) Adverse outcomes not reported Small sample size (N =44) Use of ITT analysis not reported Conducted in Europe
Moura, 2009 | Study Designation: Efficacy study Composite Score: 2 of 7 | Less stringent eligibility criteria Assessed final health outcomes | Population, Intervention, Outcomes, Setting | Baseline characteristics not reported Only patients undergoing primary PCI IRA not reported Use of antiplatelets and antithrombotic not reported Short duration of followup (270 d) Device name not reported Adverse outcomes not reported Small sample size (N =152) Use of ITT analysis not reported Conducted in South America
Sardella, 2009 | Study Designation: Efficacy study Composite Score: 3 of 7 | Enrolled primary care population Assessed final health outcomes Adequate study duration with clinically relevant treatments | Population, Outcomes, Setting | Only patients undergoing primary PCI Adverse outcomes not reported Small sample size (N =175) Use of ITT analysis not reported
Chao, 2008 | Study Designation: Efficacy study Composite Score: 3 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcome | Population, Setting | High male to female ratio (83.78 - 86.49%) Only patients undergoing primary PCI Short duration of followup (180 d) Small sample size (N =74) Use of ITT analysis not reported Conducted in Asia
Chevalier, 2008 | Study Designation: Effectiveness study Composite Score: 5 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Adequate sample size; 5. Used intention to treat analysis | Population, Setting | - High male to female ratio (80-81%); - Only patients undergoing primary PCI; - Short duration of followup (30 d); - Conducted in Europe and India
Ciszewski, 2008 | Study Designation: Efficacy study Composite Score: 2 of 7 | 1. Assessed final health outcomes; 2. Used intention to treat analysis | Population, Intervention, Outcomes, Setting | - Only patients undergoing primary PCI; - IRA not reported; - Use of antiplatelets and antithrombotic not reported; - Short duration of followup (8 d); - Rescue and Diver devices no longer available; - Adverse outcomes not reported; - Small sample size (N =135); - Conducted in Europe
Ikari, 2008 | Study Designation: Effectiveness study Composite Score: 5 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Adequate sample size; 5. Used intention to treat analysis | Population, Intervention, Setting | - High male to female ratio (77.7-80.6%); - Only patients undergoing primary PCI; - Short duration of followup (240 - 720 d); - TVAC device is not FDA approved; - Conducted in Asia
Svilaas, 2008 | Study Designation: Effectiveness study Composite Score: 6 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Adequate study duration with clinically relevant treatments; 4. Assessed adverse outcome; 5. Adequate sample size; 6. Used intention to treat analysis | Population, Setting | - High male to female ratio (67.9-73.1%); - Only patients undergoing primary PCI; - Conducted in Europe
DeLuca, 2006 | Study Designation: Efficacy study Composite Score: 2 of 7 | 1. Assessed final health outcomes; 2. Assessed adverse outcome | Population, Intervention, Setting | - High male to female ratio (55.3- 71%); - Only patients undergoing primary PCI; - Majority of IRAs were LAD (97.4-100%); - Short duration of followup (180 d); - Diver CE device no longer available; - Small sample size (N =76); - Use of ITT analysis not reported; - Conducted in Europe
Kaltoft, 2006 | Study Designation: Effectiveness study Composite Score: 5 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Adequate sample size; 5. Used intention to treat analysis | Population, Intervention, Setting | - High male to female ratio (76- 80%); - Only patients undergoing primary PCI; - Short duration of followup (30 d); - Rescue device no longer available; - Conducted in Europe
Lee, 2006 | Study Designation: Efficacy study Composite Score: 2 of 7 | 1. Enrolled primary care population; 2. Less stringent eligibility criteria | Population, Outcomes, Setting | - Only patients undergoing primary PCI; - Use of antiplatelets and antithrombotic not reported; - Final health outcomes not reported; - Short duration of followup (in-hospital); - Adverse outcomes not reported; - Small sample size (N =133); - Use of ITT analysis not reported; - Conducted in Asia
Silva-Orrego, 2006 | Study Designation: Efficacy study Composite Score: 4 of 7 | 1. Less stringent eligibility criteria; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Used intention to treat analysis | Population, Setting | - Younger population (57.3- 58.0 y); - High male to female ratio (76- 84%); - Only patients undergoing primary PCI; - Short duration of followup (180 d); - Small sample size (N =148); - Conducted in Europe
Burzotta, 2005 | Study Designation: Efficacy study Composite Score: 4 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Used intention to treat analysis | Population, Intervention, Setting | - High male to female ratio (77.6-90%); - Short duration of followup (30 d); - Diver CE device no longer available; - Small sample size (N =99); - Conducted in Europe
Noel, 2005 | Study Designation: Efficacy study Composite Score: 1 of 7 | 1. Assessed final health outcomes | Population, Outcomes, Setting | - Baseline characteristics not reported; - Percentage of primary PCI versus rescue PCI not reported; - IRA not reported; - Use of antiplatelets and antithrombotic not reported; - Short duration of followup (1 hr); - Adverse outcomes not reported; - Small sample size (N =50); - Use of ITT analysis not reported; - Conducted in Europe
Dudek, 2004 | Study Designation: Efficacy study Composite Score: 1 of 7 | 1. Less stringent eligibility criteria | Population, Intervention, Outcomes, Setting | - Younger population (56.7- 59.1 y); - High male to female ratio (69-80%); - Only patients undergoing primary PCI; - IRA not reported; - Suboptimal use of anti-thrombotics; - Final health outcomes not reported; - Short duration of followup (90 d); - Rescue device no longer available; - Small sample size (N =72); - Use of ITT analysis not reported; - Conducted in Europe

Abbreviations: d=days; FDA=Food and Drug Administration; IRA=infarct related artery; ITT=intent to treat; LAD=left anterior descending artery; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 222 Evaluation of applicability for individual randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Migliorini, 2010 | Study Designation: Effectiveness study Composite Score: 5 of 7 | Enrolled primary care population Assessed final health outcomes Adequate study duration with clinically relevant treatments Assessed adverse outcome Adequate sample size | Population | High male to female ratio (76- 81%) Only patients undergoing primary PCI Use of ITT analysis not reported
Ali, 2006 | Study Designation: Effectiveness study Composite Score: 5 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcome Adequate sample size Used intention to treat analysis | Population | High male to female ratio (74.2-75.8%) Short duration of followup (30 -180 d)
Lefèvre, 2005 | Study Designation: Efficacy study Composite Score: 4 of 7 | Assessed final health outcomes Assessed adverse outcome Adequate sample size Used intention to treat analysis | Population, Setting | High male to female ratio (73-76%) Only patients undergoing primary PCI Suboptimal use of antiplatelets Short duration of followup (180 d) Conducted in Europe
Antoniucci, 2004 | Study Designation: Efficacy study Composite Score: 4 of 7 | Enrolled primary care population Less stringent eligibility criteria Assessed final health outcomes Used intention to treat analysis | Outcome, Setting | High male to female ratio (78-82%) Only patients undergoing primary PCI Short duration of followup (30 d) Adverse outcomes not reported Small sample size (N =100) Conducted in Europe
Napodano, 2003 | Study Designation: Efficacy study Composite Score: 3 of 7 | Assessed final health outcomes Assessed adverse outcomes Used intention to treat analysis | Population, Setting | High male to female ratio (71.7-82.6%) Percentage of primary PCI versus rescue PCI not reported IRA not reported Short duration of followup (30 d) Small sample size (N =92) Conducted in Europe

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 223 Evaluation of applicability for individual randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Ito, 2010 | Study Designation: Effiacy study Composite Score: 4 of 7 | Enrolled primary care population Less stringent inclusion criteria Assessed final health outcomes Used intention to treat analysis | Intervention, Outcomes, Setting | High male to female ratio (76-79%) Filtrap not available in the US Short duration of FU (30d) Adverse outcomes not reported Small sample size (N=26) Conducted in Asia
Kelbæk, 2008 | Study Designation: Effectiveness study Composite Score: 5 of 7 | Enrolled primary care population Assessed final health outcomes Adequate study duration with clincally relevant treatments Adequate sample size Used intention to treat analysis | Population, Intervention, Outcomes, Setting | High male to female ratio (72-74.4%) Only patients undergoing primary PCI SpiderX device no longer available Adverse outcomes not reported Conducted in Europe
Cura, 2007 | Study Designation: Efficacy study Composite Score: 4 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcome Used intention to treat analysis | Population, Intervention, Setting | High male to female ratio (77-86%) Low percentage of rescue PCI (3-4%) Short duration of followup (180 d) SpiderX device no longer available Small sample size (N =140) Conducted in South America and Asia
Guetta, 2007 | Study Designation: Efficacy study Composite Score: 2 of 7 | Assessed final health outcomes Used intention to treat analysis | Population, Outcomes, Setting | Younger population (57-60 y) High male to female ratio (82%) Percentage of primary PCI versus rescue PCI not reported Short duration of followup (30 d) Adverse outcomes not reported Small sample size (N =100) Conducted in Asia
Lefèvre, 2004 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Outcomes, Setting | High male to female ratio (81- 83%) Percentage of primary PCI versus rescue PCI not reported Use of antiplatelets and antithrombotic not reported Short duration of followup (30 d) Adverse outcomes not reported Small sample size (N =60) Use of ITT analysis not reported Conducted in Europe

Abbreviations: d=days; ITT=intent to treat; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 224 Evaluation of applicability for individual randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Duan, 2010 | Study Designation: Efficacy study Composite Score: 2 of 7 | Adequate study duration with clinically relevant treatments Used intention to treat analysis | Population, Outcomes, Setting | Younger age group (55-56) High male to female ratio (82-87%) Only patients undergoing primary PCI 100% in one vessel (Left anterior descending) Final health outcomes not reported Adverse outcomes not reported Small sample size (n=96) Conducted in Asia
Pan, 2010 | Study Designation: Efficacy study Composite Score: 3 of 7 | Enrolled primary care population Adequate study duration with clinically relevant treatments Used intention to treat analysis | Outcomes, Intervention, Setting | Final health outcomes not reported Adverse outcomes not reported Small sample size (n=104) Guardwire not available in the US Conducted in Asia
Tahk, 2008 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Intervention, Outcomes, Setting | Younger population (55.9-58.8 y) High male to female ratio (71-85 %) Only patients undergoing primary PCI Short duration of followup (180 d) PercuSurge GuardWire device no longer available Adverse outcomes not reported Small sample size (N =116) ITT not used Conducted in Asia
Hahn, 2007 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Intervention, Outcomes, Setting | Younger population (55-56 y) High male to female ratio (79-95%) Only patients undergoing primary PCI Short duration of followup (180 d) GuardWire device no longer available Adverse outcomes not reported Small sample size (N =39) Use of ITT analysis not reported Conducted in Asia
Matsuo, 2007 | Study Designation: Efficacy study Composite Score: 3 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome | Population, Intervention, Setting | - High male to female ratio (76-86%); - Percentage of primary PCI versus rescue PCI not reported; - Short duration of followup (180 d); - GuardWire device no longer available; - Small sample size (N =154); - Use of ITT analysis not reported; - Conducted in Asia
Muramatsu, 2007 | Study Designation: Efficacy study Composite Score: 4 of 7 | 1. Assessed final health outcomes; 2. Assessed adverse outcome; 3. Adequate sample size; 4. Used intention to treat analysis | Population, Setting | - High male to female ratio (72.9-78.6%); - Only patients undergoing primary PCI; - Use of antithrombotic not reported; - Short duration of followup (30 d); - Conducted in Asia
Zhou, 2007 | Study Designation: Efficacy study Composite Score: 3 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome | Population, Intervention, Outcomes, Setting | - Younger population (55-57 y); - Only patients undergoing primary PCI; - Short duration of followup (in-hospital); - PercuSurge GuardWire device no longer available; - Small sample size (N =112); - Use of ITT analysis not reported; - Geographic location not reported
Okamura, 2005 | Study Designation: Efficacy study Composite Score: 0 of 7 | | Population, Intervention, Outcomes, Setting | - Younger population (59y); - High male to female ratio (75- 88%); - Percentage of primary PCI versus rescue PCI not reported; - Final health outcomes not reported; - Short duration of followup (22 d); - PercuSurge GuardWire device no longer available; - Adverse outcomes not reported; - ITT not used; - Conducted in Japan
Stone, 2005 | Study Designation: Effectiveness study Composite Score: 5 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Assessed adverse outcome; 4. Adequate sample size; 5. Used intention to treat analysis | Population | - Younger population (58.5- 59.8 y); - High male to female ratio (76.2-80.7%); - Short duration of followup (180 d)

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 225 Evaluation of applicability for individual randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Haeck, 2009 | Study Designation: Efficacy study Composite Score: 4 of 7 | Assessed final health outcomes Assessed adverse outcome Adequate sample size Used intention to treat analysis | Population, Setting | Younger population (59-62 y) High male to female ratio (80%) Only patients undergoing primary PCI Short duration of followup (30 d) Conducted in Europe and North America

Abbreviations: d=days; PCI=percutaneous coronary intervention; y=years

Table 226 Evaluation of applicability for individual randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes population

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Parikh, 2008 | Study Designation: Efficacy study Composite Score: 3 of 7 | Assessed final health outcomes Assessed adverse outcome Adequate study duration with clinically relevant treatments | Population, Intervention, Setting | Younger population (55.17-56.16 y) High male to female ratio (90-95%) Percentage of primary PCI versus rescue PCI not reported Use of antiplatelets and antithrombotic not reported GuardWire device no longer available Small sample size (N =67) Use of ITT analysis not used Conducted in Asia
Gick, 2005 | Study Designation: Efficacy study Composite Score: 4 of 7 | Enrolled primary care population Assessed final health outcomes Adequate sample size Used intention to treat analysis | Population, Intervention, Outcomes, Setting | High male to female ratio (80-86%) Percentage of primary PCI versus rescue PCI not reported Short duration of followup (30 - 180 d) FilterWire device no longer available Adverse outcomes not reported Conducted in Europe
Sardella, 2005 | Study Designation: Efficacy study Composite Score: 0 of 7 | | Population, Intervention, Outcomes, Setting | - High male to female ratio (77.42%); - Only patients undergoing primary PCI; - Use of antiplatelets and antithrombotic not reported; - Final health outcomes not reported; - Short duration of followup (post- PCI); - Diver device no longer available; - Adverse outcomes not reported; - Small sample size (N =62); - Use of ITT analysis not reported; - Geographical location not reported
Kunii, 2004 | Study Designation: Efficacy study Composite Score: 2 of 7 | 1. Assessed final health outcomes; 2. Adequate sample size | Population, Intervention, Outcomes, Setting | - High male to female ratio (76-86 %); - Only patients undergoing primary PCI; - Use of antiplatelets and antithrombotic not reported; - Short duration of followup (in-hospital); - Rescue device no longer available; - Adverse outcomes not reported; - Use of ITT analysis not reported; - Conducted in Asia
Nanasato, 2004 | Study Designation: Efficacy study Composite Score: 0 of 7 | | Population, Outcomes, Setting | - Baseline characteristics not reported; - Final health outcomes not reported; - Short duration of followup (post PCI); - Adverse outcomes not reported; - Small sample size (N =64); - Use of ITT analysis not reported; - Conducted in Asia
Matsushita, 2003 | Study Designation: Efficacy study Composite Score: 1 of 7 | 1. Assessed final health outcomes | Population, Intervention, Outcomes, Setting | - High male to female ratio (76.79-83.33); - Percentage of primary PCI versus rescue PCI not reported; - IRA not reported; - Use of antiplatelets and antithrombotic not reported; - Short duration of followup (in-hospital to 180 d); - PercuSurge GuardWire not available; - Adverse outcomes not reported; - Small sample size (N =80); - Use of ITT analysis not reported; - Conducted in Asia
Beran, 2002 | Study Designation: Efficacy study Composite Score: 3 of 7 | 1. Enrolled primary care population; 2. Assessed final health outcomes; 3. Used intention to treat analysis | Population, Outcomes, Setting | - Younger population (53.9-55.9 y); - High male to female ratio (73-77%); - Short duration of followup (30 d); - Adverse outcomes not reported; - Small sample size (N =61); - Conducted in Europe

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 227 Evaluation of applicability for individual randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Webster, 2008 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Outcomes, Setting | Younger population (58- 60 y) High male to female ratio (83-89%) Percentage of primary PCI versus rescue PCI not reported Use of antiplatelets and antithrombotic not reported Short duration of followup (30 d) Adverse outcomes not reported Small sample size (N =151) Use of ITT analysis not reported Conducted in Australia and North Americ
Dudek, 2003 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed final health outcomes | Population, Outcomes, Setting | Younger population (49.3-59.4 y) Percentage of primary PCI versus rescue PCI not reported IRA not reported Short duration of followup (30 d) AngioGuard not available Adverse outcomes not reported Small sample size (N =31) Use of ITT analysis not reported Conducted in Europe

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 228 Evaluation of applicability for individual direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Sardella, 2008 | Study Designation: Effectiveness study Composite Score:4 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcome Used intention to treat analysis | Population, Intervention, Setting | High male to female ratio (78.4-78.8%) Only patients undergoing primary PCI Diver not available Small sample size (N =103) Conducted in Europe
Yan, 2007 | Study Designation: Efficacy study Composite Score: 3 of 7 | Assessed final health outcomes Assessed adverse outcome Used intention to treat analysis | Population, Intervention, Setting | High male to female ratio (82-84%) Only patients undergoing primary PCI Majority of IRAs were RCA (100%) Short duration of followup (30 d) Diver CE device no longer available Small sample size (N =122) Conducted in Asia

Abbreviations: d=days; IRA=infarct related artery; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; RCA=right coronary artery

Table 229 Evaluation of applicability for individual randomized controlled trials with selective inclusion/exclusion criteria in patient with ST-segment elevation myocardial infarction

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Wita, 2009 | Study Designation: Efficacy study Composite Score: 1 of 7 | Assessed adverse outcome | Population, Intervention, Outcomes, Setting | Younger population (56.6- 58.1 y) High male to female ratio (70.9-79%) Percentage of primary PCI versus rescue PCI not reported Majority of IRAs were LAD (100%) Final health outcomes not reported Short duration of followup (post-PCI - 30 d) Diver CE device no longer available Small sample size (N =42) Use of ITT analysis not reported Conducted in Europe
Ozaki, 2006 | Study Designation: Efficacy study Composite Score: 0 of 7 | | Population, Intervention, Outcomes, Setting | Only male patients (100%) Only patients undergoing primary PCI IRA not reported Final health outcomes not reported Short duration of followup (180 d) Rescue, Thrombuster, PercuSurge GuardWire devices no longer available Adverse outcomes not reported Small sample size (N =77) Use of ITT analysis not reported Conducted in Asia

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; LAD=left anterior descending artery; N=total number of patients enrolled in the study; PCI=percutaneous coronary intervention; y=years

Table 230 Evaluation of applicability for individual observational studies

Study, Year | Effectiveness Study Designation and Composite Score | Effectiveness Study Criteria Met | Applicability Limitation Category | Specific Factors Limiting Applicability
Beaudoin, 2010 | Study Designation: Effectiveness study Composite Score: 6 of 7 | Enrolled primary care population Less stringent inclusion criteria Assessed final health outcomes Adequate study duration with clinically relevant treatments Asssessed adverse health outcome Adequate sample size | Population | High male to female ratio (70-76%) IRA not reported Conducted in Canada ITT analysis not used
Kim, 2010 | Study Designation: Efficacy study Composite Score: 3 of 7 | Less stringent inclusion criteria Assessed final health outcomes Adequate sample size | Intervention, Outcomes, Setting | High male to female ratio (72.7-77.6%) Short duration of FU (30d) Aspiration catheter device name not reported Adverse outcomes not reported ITT analysis not used Conducted in Asia
Ko, 2009 | Study Designation: Efficacy study Composite Score: 2 of 7 | Assessed final health outcomes Adequate sample size | Population, Intervention, Outcomes, Setting | Younger population (58 y) High male to female ratio (72.5%) Percentage of primary PCI versus rescue PCI not reported IRA not reported Use of antiplatelets and antithrombotic not reported Distal protection device name not reported Adverse outcomes not reported ITT analysis not used Conducted in Asia
Nilsen, 2009 | Study Designation: Efficacy study Composite Score: 3 of 7 | Assessed final health outcomes Assessed adverse outcome Adequate sample size | Population, Intervention, Setting | Baseline characteristics not reported Only patients undergoing primary PCI IRA not reported Use of antiplatelets and antithrombotic not reported Short duration of followup (30 d) Aspiration catheter device name not reported ITT analysis not used Geographic location not reported
Nakatani, 2007 | Study Designation: Efficacy study Composite Score: 2 of 7 | Assessed final health outcomes Adequate sample size | Population, Interventions, Outcomes, Setting | High male to female ratio (76.7-79.8%) Only patients undergoing primary PCI Use of antiplatelets and antithrombotic not reported Short duration of followup (30 d) Rescue, Thrombuster, TVAC devices no longer available Adverse outcomes not reported ITT analysis not used Conducted in Asia
Chinnaiyan, 2006 | Study Designation: Efficacy study Composite Score: 4 of 7 | Enrolled primary care population Assessed final health outcomes Assessed adverse outcome Adequate sample size | Population, Setting | Use of antiplatelets not reported Short duration of followup (in-hospital) ITT analysis not used Geographic location not reported
Simonton, 2006 | Study Designation: Efficacy study Composite Score: 2 of 7 | Assessed final health outcomes Adequate sample size | Population, Outcomes | Baseline characteristics not reported Percentage of primary PCI versus rescue PCI not reported IRA not reported Use of antiplatelets and antithrombotic not reported Short duration of followup (270 d) Adverse outcomes not reported ITT analysis not used

Abbreviations: d=days; IRA=infarct related artery; ITT=intent to treat; TVAC=transvascular aspiration catheter; PCI=percutaneous coronary intervention; y=year

Table 231 Strength of applicability for the body of evidence evaluating mortality in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of mortality. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of mortality. Overall data is limited because the Diver CE device is not currently available in the US and the study was of short duration. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in the risk of mortality. Overall applicability of the data is limited because a large majority of studies were conducted outside of the US and did not allow for adequate study duration to assess mortality. While the data is highly applicable to male patients with STEMI undergoing primary PCI, applicability of data is moderate in female patients, and low in patients with other ACS or those undergoing rescue PCI.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of mortality. Overall applicability of data is limited because the majority of studies were conducted outside of the US and did not allow for adequate duration of followup to assess mortality. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is low in patients with other ACS. Applicability is moderate in female patients and in patients undergoing rescue PCI.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of mortality. Overall applicability of data is limited because all studies were conducted outside of the US, more than half of the data is derived from studies which evaluated a device that is not currently available in the US, and the majority of studies did not allow for adequate duration of followup to assess mortality. The data is highly applicable to male patients with STEMI and moderately applicable to patients with other ACS and female patients.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of mortality. Overall applicability of data is limited because less than half of the data is derived from studies conducted within the US and most studies did not allow for adequate study duration to assess mortality. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients undergoing rescue PCI or in patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of mortality. Applicability of the data is limited because the representative study was conducted outside of the US and did not allow for adequate followup to assess mortality. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of mortality. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess mortality. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States;Y=years

Table 232 Strength of applicability for the body of evidence evaluating myocardial infarction in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of myocardial infarction. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of myocardial infarction. Overall data is limited because the Diver CE device is not currently available in the US and the study was of short durtation. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in the risk of myocardial infarction. Overall applicability is limited because the majority of studies were conducted outside of the US and did not allow for adequate study duration to assess myocardial infarction. While the data is highly applicable to male patients with STEMI undergoing primary PCI, applicability of data is moderate in female patients, and low in patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of myocardial infarction. Overall, the majority of studies were conducted outside of the US and did not allow for adequate duration of followup to assess myocardial infarction. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is low in patients with other ACS. Applicability is moderate in female patients and in patients undergoing rescue PCI.
Distal filter embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk off myocardial infarction. Overall data is limited because all studies were conducted outside of the US and the majority of studies did not allow for adequate duration of followup to assess myocardial infarction. The data is highly applicable to male patients with STEMI and moderately applicable to patients with other ACS and female patients.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of myocardial infarction. Overall applicability of data is limited because less than half of the data is derived from studies conducted within the US and most studies did not allow for adequate study duration to assess myocardial infarction. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of myocardial infarction. Data is limited because the representative study was conducted outside of the US and did not allow for adequate followup to assess myocardial infarction. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of myocardial infarction. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess myocardial infarction. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 233 Strength of applicability for the body of evidence evaluating stroke in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in the risk of stroke. Applicability is limited by duration of followup as the majority of studies did not allow for adequate duration to stroke. While the data is highly applicable to male patients with STEMI undergoing primary PCI, applicability of data is moderate in female patients, and low in patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of stroke. Overall, the majority of studies were conducted outside of the US and did not allow for adequate duration of followup to stroke. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is moderate in female patients and patients undergoing rescue PCI. Data is not applicable to other patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients undergoing native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of stroke. Data has limited applicability because all studies were conducted in Europe and mostly devices evaluated are not available in the US. The majority of studies did not allow for adequate duration of followup to assess stroke. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS.
Distal balloon embolic protection devices versus control | High | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of stroke. Overall applicability of data is limited because the study did not allow for adequate duration to assess stroke. The data is highly applicable to male patients with STEMI undergoing primary or rescue PCI. The data is moderately applicable to female patients and not applicable to patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of stroke. Data is limited because the representative study was conducted outside of the US and did not allow for adequate followup to assess stroke. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of stroke. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess stroke. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 234 Strength of applicability for the body of evidence evaluating target revascularization in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of target revascularization. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of target revascularization. Overall data is limited because the Diver CE device is not currently available in the US and the study was of short duration. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in the risk of target revascularization. Overall applicability is limited because the majority of studies were conducted outside of the US and did not allow for adequate study duration to assess target revascularization. While the data is highly applicable to male patients with STEMI undergoing primary PCI, applicability of data is moderate in female patients, and low in patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of target revascularization. Overall, the majority of studies were conducted outside of the US and did not allow for adequate duration of followup to assess target revascularization. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is low in patients with other ACS. Applicability is moderate in female patients and in patients undergoing rescue PCI.
Distal filter embolic protection devices versus control | Moderate | Compared to control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of target revascularization. Overall, all studies were conducted outside of the US and the majority of studies did not allow for adequate duration of followup to assess target revascularization. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and in patients with other ACS, although low in patients undergoing rescue PCI.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of target revascularization. Overall applicability of data is limited because less than half of the data is derived from studies conducted within the US and most studies did not allow for adequate study duration to assess target revascularization. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of target revascularization. Data is limited because the representative study was conducted outside of the US and did not allow for adequate followup to assess target revascularization. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of target revascularization. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess target revascularization. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 235 Strength of applicability for the body of evidence evaluating major adverse cardiac events in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of major adverse cardiovascular events. Overall data is limited because the Diver CE device is not currently available in the US and the study was of short duration. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared to control, patients who undergo native vessel PCI with a catheter aspiration device have a decreased risk of major adverse cardiovascular events. The overall applicability is limited because a majority of studies were conducted outside of the US and did not allow for adequate duration of followup to assess major adverse cardiovascular events. The applicability of the data is high in male patients with STEMI undergoing primary PCI and moderate in female patients. Applicability is low in patients undergoing rescue PCI and is not applicable in patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of major adverse cardiovascular events. Overall, the majority of studies were conducted outside of the US and did not allow for adequate duration of followup to assess major adverse cardiovascular events. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is low in patients with other ACS. Applicability is moderate in female patients and in patients undergoing rescue PCI.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of major adverse cardiovascular events. Overall data is limited because all studies were conducted outside of the US, the majority of studies did not allow for adequate duration of followup to assess major adverse cardiovascular events, and the majority of the data is derived from studies which evaluated a device that is not currently available in the US. The data is highly applicable to male patients with STEMI and moderately applicable to patients with other ACS and female patients.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of major adverse cardiovascular events. Overall applicability of data is limited because less than half of the data is derived from studies conducted within the US and most studies did not allow for adequate study duration to assess major adverse cardiovascular events. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients undergoing rescue PCI or in patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of major adverse cardiovascular events. Data is limited because the representative study was conducted outside of the US and did not allow for adequate followup to assess major adverse cardiovascular events. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of major adverse cardiovascular events. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess major adverse cardiovascular events. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 236 Strength of applicability for the body of evidence evaluating resolution of ST-segment elevation in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of resolving ST-segment elevation. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of resolving ST-segment elevation. Overall data is limited because the Diver CE device is not currently available in the US. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device have an increased risk in resolving ST-segment elevation. The overall applicability is limited because the majority of studies were conducted outside of the US. Data is highly applicable in male patients with STEMI undergoing primary PCI and is moderately applicable to female patients. Data has low applicability to patients undergoing rescue PCI and is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of resolving ST-segment elevation. Overall applicability of the data is limited because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI while applicability is moderate in female patients and patients undergoing rescue PCI. Data is not applicable to other patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of resolving ST-segment elevation. Overall applicability of the data is limited because all studies were conducted outside of the US and the majority of data is derived from studies which evaluated a device that is no longer available in the US. Data is highly applicable to male patients with ST segment elevation myocardial infarction undergoing primary PCI and moderately applicable in female patients. Data is not applicable to patients with other ACS.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of resolving ST-segment elevation. Overall applicability of data is limited because less than half of the data is derived from studies conducted within the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients undergoing rescue PCI. Data is not applicable to patients with other ACS.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of resolving ST-segment elevation. Data is limited because the representative study was conducted outside of the US. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of major adverse cardiovascular events. Applicability of the data is limited because a majority of the studies were conducted outside of the US and did not allow for adequate followup to assess major adverse cardiovascular events. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients undergoing rescue PCI and is not applicable to patients with other ACS.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 237 Strength of applicability for the body of evidence evaluating ejection fraction in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in ejection fraction. Overall applicability is limited because the majority of data is derived from studies which evaluated devices that are not currently available in the US and most studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable in female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable in patients with other ACS.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared with catheter aspiration devices, patients undergoing native vessel PCI with distal balloon embolic protection devices do not have a difference in ejection fraction. Overall data is limited because the data is derived from studies which were conducted in Asia and evaluated devices that are not currently available in the US. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in ejection fraction. Overall the data has limited applicability because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI regardless if primary or rescue PCI and moderately applicable in female patients. Data is not applicable in patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in ejection fraction. Overall data is limited because all studies were conducted outside of the US and the majority of data is derived from studies which evaluated a device that is not currently available in the US. Data is moderately applicable to patients with ACS undergoing primary PCI.
Distal balloon embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in ejection fraction. Overall applicability is limited because all studies were conducted outside of the US and close to half of the data is derived from studies which evaluated a device that is not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS. Data is not applicable to patients undergoing rescue PCI.
Embolic protection devices combined versus control | Low | Compared with control, patient who undergo native vessel PCI with an embolic protection device do not have a difference in ejection fraction. Applicability of the data is limited because a majority of the studies were conducted outside of the US and evaluated devices not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States

Table 238 Strength of applicability for the body of evidence evaluating myocardial blush grade of 3 in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of attaining a MBG-3. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of attaining a MBG-3. Overall data is limited because the Diver CE device is not currently available in the US. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device have an increased risk in attaining a MBG-3. Overall applicability is limited because the majority of studies were conducted outside of the US. Data is highly applicable in male patients with STEMI undergoing primary PCI and is moderately applicable to female patients. Data has low applicability to patients undergoing rescue PCI and is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of attaining a MBG-3. Overall the data has limited applicability because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI and moderately applicable in female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable in patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of attaining a MBG-3. Overall data is limited because all studies were conducted outside of the US and the majority of data is derived from studies which evaluated a device that is not currently available in the US. Data is moderately applicable to patients with ACS undergoing primary PCI.
Distal balloon embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device have an increased risk in attaining a MBG-3. Overall applicability is limited because a majority of studies were conducted outside of the US and close to half of the data is derived from studies which evaluated a device that is not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS or undergoing rescue PCI.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of attaining a MBG-3. Data is limited because the representative study was conducted outside of the US. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Low | Compared with control, patients who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of attaining a MBG-3. Applicability of the data is limited because a majority of the studies were conducted outside of the US and evaluated devices not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI

Abbreviations: ACS=Acute coronary syndrome; MBG= Myocardial blush grade; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 239 Strength of applicability for the body of evidence evaluating TIMI-3 blood flow in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus catheter aspiration | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of attaining TIMI-3 blood flow. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of attaining TIMI-3 blood flow. Overall data is limited because the Diver CE device is not currently available in the US. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device have an increased risk in attaining a TIMI-3 blood flow. The overall applicability is limited because a majority of data is derived from studies conducted outside of the US. Data is highly applicable to male patients with STEMI and moderately applicable in female patients Data has low applicability in patients with other ACS and in patients undergoing rescue PCI.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of attaining a TIMI-3 blood flow. Overall the data has limited applicability because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI and moderately applicable in female patients and patient undergoing rescue PCI. Data has low applicability in patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of attaining a TIMI-3 blood flow. Overall data is limited because all studies were conducted outside of the US and more than half of the data is derived from studies which evaluated a device that is not currently available in the US. The data is highly applicable to male patients with STEMI and moderately applicable to patients with other ACS and female patients.
Distal balloon embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk in attaining TIMI-3 blood flow. Overall applicability is limited because a majority of studies were conducted outside of the US and close to half of the data is derived from studies which evaluated a device that is not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS or undergoing rescue PCI.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of attaining TIMI-3 blood flow. Data is limited because the representative study was conducted outside of the US. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Low | Compared with control, patients who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of attaining TIMI-3 blood flow. Applicability of the data is limited because a majority of the studies were conducted outside of the US and evaluated devices not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; TIMI=Thrombolysis in myocardial infarction; US=United States; Y=years

Table 240 Strength of applicability for the body of evidence evaluating distal embolization in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device have a decreased risk of distal embolization. Overall applicability is limited because a majority of data is derived from studies which evaluated devices that are not currently available in the US and most studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of distal embolization. Overall the data has limited applicability because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI and moderately applicable in female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable to patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of distal embolization. Overall data is limited because all studies were conducted outside of the US and the majority of data is derived from studies which evaluated a device that is not currently available in the US. Data is applicable to patients with ACS undergoing primary PCI.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of distal embolization. Overall applicability is limited because a majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS or undergoing rescue PCI.
Proximal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of distal embolization. Data is limited because the representative study was conducted outside of the US. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patients who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of distal embolization. Applicability of the data is limited because a majority of the studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=years

Table 241 Strength of applicability for the body of evidence evaluating no reflow in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device have a decreased risk of no reflow. Overall applicability is limited because all studies were conducted outside of the US and almost half of the data is derived from studies which evaluate devices that are not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable in patients with other ACS.
Catheter aspiration versus distal balloon embolic protection device | Low | Compared to the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a difference in the risk of no reflow. Overall data is limited because the Diver CE device is not currently available in the US. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Mechanical thrombectomy devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of no reflow. Overall the data has limited applicability because the majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI and moderately applicable in female patients. Data has low applicability in patients undergoing rescue PCI and is not applicable to patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients who undergo native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of no reflow. Overall data is limited because all studies were conducted outside of the US and the majority of data is derived from studies which evaluated a device that is not currently available in the US. Data is applicable to patients with ACS undergoing primary PCI.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of no reflow. Overall applicability is limited because a majority of studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and has low applicability to patients with other ACS or undergoing rescue PCI.
Embolic protection devices combined versus control | Moderate | Compared with control, patients who undergo native vessel PCI with an embolic protection device do not have a difference in the risk of no reflow. Applicability of the data is limited because a majority of the studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI and moderately applicable to female patients. The data has low applicability in patients with other ACS or undergoing rescue PCI

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States; Y=Years

Table 242 Strength of applicability for the body of evidence evaluating coronary dissection in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration device versus catheter aspiration device | Low | Compared with the catheter aspiration device Export, patients who undergo native vessel PCI with the catheter aspiration device Diver do not have a difference in the risk of coronary dissection. Applicability is limited because the trial was conducted in Italy and the Diver device is not available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is not applicable to patients with other ACS or undergoing rescue PCI.
Catheter aspiration devices versus control | Moderate | Compared with control, patients who undergo native vessel PCI with a catheter aspiration device do not have a difference in the risk of coronary dissection. Applicability is limited because all studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients and is not applicable to patients with other ACS or those undergoing rescue PCI.
Mechanical thrombectomy devices versus control | High | Compared with control, patients who undergo native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of coronary dissection. Data is highly applicable to patients with STEMI undergoing primary or rescue PCI. Data is not applicable to patients with other ACS.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States

Table 243 Strength of applicability for the body of evidence evaluating coronary perforation in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Mechanical thrombectomy devices versus control | High | Compared with control, patients undergoing native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of coronary perforation. Data is highly applicable to patients with STEMI undergoing primary or rescue PCI although is not applicable to patients with other ACS.
Distal balloon embolic protection devices versus control | Low | Compared with control, patients undergoing native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of coronary perforation. Applicability is limited because the trial evaluated a device which is not currently available in the US. Data is highly applicable in patients with STEMI undergoing primary PCI. Data is not applicable to patients undergoing rescue PCI or those with other ACS.
Embolic protection devices combined versus control | Low | Compared with control, patients undergoing native vessel PCI with an embolic protection device do not have a difference in the risk of coronary perforation. Applicability is limited because the trial evaluated a device which is not currently available in the US. Data is highly applicable in patients with STEMI undergoing primary PCI. Data is not applicable to patients undergoing rescue PCI or those with other ACS.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States

Table 244 Strength of applicability for the body of evidence evaluating prolonged procedure time in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration device versus distal balloon embolic protection device | Low | Compared with the catheter aspiration device Diver CE, patients undergoing native vessel PCI with the distal balloon embolic protection device Guardwire Plus do not have a prolonged procedure time. Overall data is limited because the Diver CE device is not currently available in the US and the study was of short duration. Data is highly applicable to Asian male patients with STEMI undergoing primary PCI on the right coronary artery.
Catheter aspiration versus control | Moderate | Compared with control, patients undergoing native vessel PCI with a catheter aspiration device do not have a prolonged procedure time. Applicability is limited because all studies were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. The data is moderately applicable to female patients, has low applicability in patients undergoing rescue PCI, and is not applicable to patients with other ACS.
Mechanical thrombectomy devices versus control | High | Compared with control, patients undergoing native vessel PCI with a mechanical thrombectomy device have a prolonged procedure time. Data is highly applicable to male patients with STEMI undergoing primary PCI. The data is moderately applicable to female patients or those undergoing rescue PCI, and is not applicable to patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients undergoing native vessel PCI with a distal filter embolic protection device have a prolonged procedure time. Applicability is limited because this study was conducted in South American and Asia and evaluated a device that is not currently available in the US. Data is highly applicable to male patients with STEMI undergoing primary PCI. The data is moderately applicable to female patients, has low applicability to patients undergoing rescue PCI and is not applicable to patients with other ACS.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients undergoing native vessel PCI with a distal balloon embolic protection device have a prolonged procedure time. Overall data is limited because half is derived from trials conducted in Asia and India. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to female patients or those with other ACS and has low applicability in patients undergoing rescue PCI.
Proximal balloon embolic protection device versus control | Low | Compared with control, patients who undergo native vessel PCI with a proximal balloon embolic protection device do not have a difference in the risk of prolonged procedure time. Data is limited because the representative trial was conducted outside of the US. Data is highly applicable to male patients of a younger mean age (less than 60Y) with STEMI undergoing primary PCI.
Embolic protection devices combined versus control | Low | Compared with control, patients who undergo native vessel PCI with an embolic protection device have a prolonged procedure time. Applicability is limited because most of the trials were conducted outside of the US. Data is highly applicable to male patients with STEMI undergoing primary PCI with moderate applicability to female patients. Data has low applicability to patients with other ACS or those undergoing rescue PCI.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States

Table 245 Strength of applicability for the body of evidence evaluating side branch occlusion in patients with acute coronary syndromes

Comparison | Strength of Applicability | Conclusion with Description of Applicability
Catheter aspiration versus control | Moderate | Compared with control, patients undergoing native vessel PCI with a catheter aspiration device do not have a difference in the risk of side branch occlusion. Overall applicability is limited because data is derived from Europe and India. Data is highly applicable to male patients with STEMI undergoing primary PCI with moderate applicability to female patients. Data is not applicable to patients undergoing rescue PCI or patients with other ACS.
Mechanical thrombectomy devices versus control | Low | Compared with control, patients undergoing native vessel PCI with a mechanical thrombectomy device do not have a difference in the risk of side branch occlusion. Data is highly applicable to male patients in Europe with STEMI and moderately applicable to female patients. Data is not applicable to patients with other ACS.
Distal filter embolic protection devices versus control | Low | Compared with control, patients undergoing native vessel PCI with a distal filter embolic protection device do not have a difference in the risk of side branch occlusion. Data is highly applicable to male patients in South America and Asia with STEMI undergoing primary PCI, with moderate applicability in female patients. The device evaluated in this trial is not currently available in the US. Data has low applicability in patients undergoing rescue PCI and is not applicable to patients with other ACS.
Distal balloon embolic protection devices versus control | Moderate | Compared with control, patients undergoing native vessel PCI with a distal balloon embolic protection device do not have a difference in the risk of side branch occlusion. Data is highly applicable to male patients with STEMI undergoing either primary or rescue PCI. Data is moderately applicable to female patients and is not applicable to patients with other ACS.
Embolic protection devices combined versus control | Moderate | Compared with control, patients undergoing native vessel PCI with an embolic protection device do not have a difference in the risk of side branch occlusion. Data is highly applicable to male patients with STEMI undergoing primary PCI. Data is moderately applicable to patients undergoing rescue PCI and is not applicable to patients with other ACS.

Abbreviations: ACS=Acute coronary syndrome; PCI=Percutaneous coronary intervention; STEMI=ST-segment elevation myocardial infarction; US=United States