# Strength of Evidence for Outcomes

Table 181 Strength of evidence for intermediate and final health outcomes for catheter aspiration devices versus distal balloon embolic protection devices in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | NA | No serious indirectness | NA | None | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Ejection fraction | 2 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Myocardial blush grade 3 | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Thrombolysis in myocardial infarction -3 | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important

Abbreviation: NA=not applicable; RCT=randomized controlled trials

Table 182 Strength of evidence for intermediate and final health outcomes for catheter aspiration devices versus catheter aspiration devices in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | NA | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Thrombolysis in myocardial infarction -3 | 1 | RCT | No serious limitation | NA | No serious indirectness | No imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 183 Strength of evidence for intermediate and final health outcomes for catheter aspiration devices versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 13 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Myocardial infarction | 12 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Stroke | 6 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Target revascularization | 11 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Major adverse cardiac events | 13 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 16 | RCTs and Observational study | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Moderate | Important
Ejection fraction | 12 | RCTs and Observational study | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Moderate | Important
Myocardial blush grade 3 | 13 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Moderate | Important
Thrombolysis in myocardial infarction -3 | 15 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Distal embolization | 11 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important
No reflow | 8 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important

Abbreviation: RCT=randomized controlled trials

Table 184 Strength of evidence for intermediate and final health outcomes for mechanical thrombectomy devices versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 5 | RCTs and Observational study | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Insufficient | Important
Myocardial infarction | 4 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Stroke | 5 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Target revascularization | 4 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 4 | RCTs and Observational study | No serious limitation | Serious Inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 5 | RCTs | No serious limitation | Serious Inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Ejection fraction | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Myocardial blush grade 3 | 4 | RCTs | No serious limitation | Serious Inconsistency | No serious indirectness | Serious imprecision | None | Low | Important
Thrombolysis in myocardial infarction-3 | 5 | RCTs and Observational study | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Moderate | Important
Distal embolization | 3 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
No reflow | 3 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 185 Strength of evidence for intermediate and final health outcomes for distal filter embolic protection devices versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Myocardial Infarction | 4 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Target revascularization | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Major adverse cardiac events | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Ejection fraction | 2 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Low | Important
Myocardial blush grade 3 | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Thrombolysis in myocardial infarction-3 | 5 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Low | Important
Distal Embolization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
No reflow | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 186 Strength of evidence for intermediate and final health outcomes for distal balloon embolic protection devices versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 4 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Myocardial infarction | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Target revascularization | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 4 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Ejection fraction | 6 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Myocardial blush grade 3 | 6 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important
Thrombolysis in myocardial infarction-3 | 8 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Low | Important
Distal embolization | 4 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
No reflow | 4 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 187 Strength of evidence for intermediate and final health outcomes for proximal balloon embolic protection devices versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Distal Embolization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 188 Strength of evidence for intermediate and final health outcomes for embolic protection devices combined versus control in ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 10 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | Insufficient | Important
Myocardial Infarction | 10 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Stroke | 3 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Target revascularization | 8 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 12 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 10 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Low | Important
Ejection fraction | 9 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Myocardial blush grade 3 | 9 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | No serious imprecision | None | Moderate | Important
Thrombolysis in myocardial infarction-3 | 14 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Low | Important
Distal Embolization | 6 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious inconsistency | None | Moderate | Important
No reflow | 6 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 189 Strength of evidence for intermediate and final health outcomes for catheter aspiration devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 2 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
St-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Low | Important
Thrombolysis in myocardial infarction-3 | 2 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 190 Strength of evidence for intermediate and final health outcomes for mechanical thrombectomy devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 2 | RCT and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | Observational study | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 2 | RCT and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 2 | RCT and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 2 | RCT and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 191 Strength of evidence for intermediate and final health outcomes for distal filter embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Distal embolization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 192 Strength of evidence for intermediate and final health outcomes for distal balloon embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | --- | --- | --- | --- | --- | --- | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important
Ejection fraction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
Myocardial blush grade 3 | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Thrombolysis in myocardial infarction-3 | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Distal Embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | High | Important

Abbreviation: RCT=randomized controlled trials

Table 193 Strength of evidence for intermediate and final health outcomes for proximal balloon embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 0 | - | - | - | - | - | - | Insufficient | Important
Distal Embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Table 194 Strength of evidence for intermediate and final health outcomes for combined embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 3 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important
Ejection fraction | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial blush grade 3 | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important
Thrombolysis in myocardial infarction-3 | 3 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Distal Embolization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
No reflow | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | High | Important

Abbreviation: RCT=randomized controlled trials

Table 195 Strength of evidence for intermediate and final health outcomes for catheter aspiration devices versus control in unstable angina/non-ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 0 | - | - | - | - | - | - | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Table 196 Strength of evidence for intermediate and final health outcomes for mechanical thrombectomy devices versus control in unstable angina/non-ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 0 | - | - | - | - | - | - | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Table 197 Strength of evidence for intermediate and final health outcomes for distal filter embolic protection devices versus control in unstable angina/non-ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 198 Strength of evidence for intermediate and final health outcomes for distal balloon embolic protection devices versus control in unstable angina/non-ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 0 | - | - | - | - | - | - | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Table 199 Strength of evidence for intermediate and final health outcomes for proximal balloon embolic protection devices versus control in unstable angina/non-ST-elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial infarction | 0 | - | - | - | - | - | - | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 0 | - | - | - | - | - | - | Insufficient | Important
Major adverse cardiac events | 0 | - | - | - | - | - | - | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 0 | - | - | - | - | - | - | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 0 | - | - | - | - | - | - | Insufficient | Important

Table 200 Strength of evidence for intermediate and final health outcomes for combined embolic protection devices versus control in unstable angina/non-ST-segment elevation myocardial infarction patients under key question 1

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Mortality | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Myocardial infarction | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Stroke | 0 | - | - | - | - | - | - | Insufficient | Important
Target revascularization | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Major adverse cardiac events | 1 | RCT | No Serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Insufficient | Important
Health-related quality of life | 0 | - | - | - | - | - | - | Insufficient | Important
ST-segment resolution | 0 | - | - | - | - | - | - | Insufficient | Important
Ejection fraction | 0 | - | - | - | - | - | - | Insufficient | Important
Myocardial blush grade 3 | 0 | - | - | - | - | - | - | Insufficient | Important
Thrombolysis in myocardial infarction-3 | 1 | RCT | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Distal embolization | 0 | - | - | - | - | - | - | Insufficient | Important
No reflow | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 201 Strength of evidence for adverse outcomes for catheter aspiration devices versus distal balloon embolic protection devices in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 202 Strength of evidence for adverse outcomes for catheter aspiration devices versus catherter aspiration devices in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 1 | RCT | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Insufficient | Important
Perforation | 1 | RCT | No serious limitation | NA | No serious indirectness | NA | None | Insufficient | Important
Prolonged procedure time | 1 | RCT | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 203 Strength of evidence for adverse outcomes for catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 5 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important
Perforation | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Prolonged procedure time | 9 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important

Abbreviation: RCT=randomized controlled trials

Table 204 Strength of evidence for adverse outcomes for mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Perforation | 3 | RCTs and Observational study | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Prolonged procedure time | 3 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | High | Important

Abbreviation: RCT=randomized controlled trials

Table 205 Strength of evidence for adverse outcomes for distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
Perforation | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
Prolonged procedure time | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important

Abbreviation: RCT=randomized controlled trials

Table 206 Strength of evidence for adverse outcomes for distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 1 | RCT | No serious limitation | Not graded | No serious indirectness | No serious imprecision | None | Insufficient | Important
Perforation | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Prolonged procedure time | 3 | RCTs | No serious limitation | Serious inconsistency | No serious indirectness | Serious imprecision | None | Low | Important

Abbreviation: RCT=randomized controlled trials

Table 207 Strength of evidence for adverse outcomes for proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important

Abbreviation: RCT=randomized controlled trials

Table 208 Strength of evidence for adverse outcomes for embolic protection devices combined versus control in patients with ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | No serious imprecision | None | Insufficient | Important
Perforation | 2 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Very serious imprecision | None | Insufficient | Important
Prolonged procedure time | 5 | RCTs | No serious limitation | No serious inconsistency | No serious indirectness | Serious imprecision | None | Moderate | Important

Abbreviation: RCT=randomized controlled trials

Table 209 Strength of evidence for adverse outcomes for catheter aspiration devices versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 210 Strength of evidence for adverse outcomes for mechanical thrombectomy devices versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 211 Strength of evidence for adverse outcomes for distal filter embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 212 Strength of evidence for adverse outcomes for distal balloon embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important

Abbreviation: RCT=randomized controlled trials

Table 213 Strength of evidence for adverse outcomes for proximal balloon embolic protection devices versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 214 Strength of evidence for adverse outcomes for embolic protection devices combined versus control in patients with mixed acute coronary syndromes under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 1 | RCT | No serious limitation | Not graded | No serious indirectness | Serious imprecision | None | Moderate | Important

Abbreviation: RCT=randomized controlled trials

Table 215 Strength of evidence for adverse outcomes for catheter aspiration devices versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 216 Strength of evidence for adverse outcomes for mechanical thrombectomy devices versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 217 Strength of evidence for adverse outcomes for distal filter embolic protection devices versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 218 Strength of evidence for adverse outcomes for distal balloon embolic protection devices versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 219 Strength of evidence for adverse outcomes for proximal balloon embolic protection devices versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important

Table 220 Strength of evidence for adverse outcomes for embolic protection devices combined versus control in patients with unstable angina/non-ST-segment elevation myocardial infarction under key question 2

| | Quality Assessment | | | | | | Summary of Findings
Outcome | Number of Studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other Considerations | Quality | Importance
Coronary dissection | 0 | - | - | - | - | - | - | Insufficient | Important
Perforation | 0 | - | - | - | - | - | - | Insufficient | Important
Prolonged procedure time | 0 | - | - | - | - | - | - | Insufficient | Important