# Additional Evidence Tables and Reference List

Table 39 Mortality in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Dudek, 2010 | Diver CE | Death | 3/100 | --- | 4/100 | ---
Dudek, 2010 | Control | | 3/96 | --- | 3/96 | ---
Liistro, 2009 | Export Thrombectomy Catheter | Cardiac death | --- | --- | 1/55 | ---
Liistro, 2009 | Control | | --- | --- | 0/56 | ---
Lipiecki, 2009 | Export Catheter | --- | --- | --- | --- | ---
Lipiecki, 2009 | Control | | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | --- | ---
Moura, 2009 | Control | | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | Death | 0/88 | 0/88 | 0/88^*^ | 0/88^#^
Sardella, 2009 | Control | 720-day: cardiac death | 1/87 | 1/87 | 1/87^*^ | 6/87^#^
Chao, 2008 | Export Aspiration Catheter | Death | --- | --- | 1/37 | ---
Chao, 2008 | Control | | --- | --- | 0/34 | ---
Chevalier, 2008 | Export Aspiration Catheter | Cardiac+ non-cardiac death | --- | 4/120 | --- | ---
Chevalier, 2008 | Control | | --- | 5/129 | --- | ---
Ciszewski, 2008 | Rescue/Diver | Death | 5/135^†^ | --- | --- | ---
Ciszewski, 2008 | Control | | | --- | --- | ---
Ikari, 2008 | TVAC | Death | 1/178 | --- | 2/170^‡^ | ---
Ikari, 2008 | Control | | 1/171 | --- | 1/158^‡^ | ---
Svilaas, 2008 | 6F Export Aspiration Catheter | Death | --- | 11/529 | --- | 25/535^**^
Svilaas, 2008 | Control | | --- | 21/531 | --- | 41/536^**^
DeLuca, 2006 | Diver CE | Death | --- | --- | 0/35 | 2/20^*^
DeLuca, 2006 | Control | | --- | --- | 2/38 | 4/28^*^
Kaltoft, 2006 | Rescue Catheter | Death | --- | 0/108 | --- | ---
Kaltoft, 2006 | Control | | --- | 1/107 | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | --- | ---
Lee, 2006 | Control | | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | Death | 0/74 | --- | 0/74 | ---
Silva-Orrego, 2006 | Control | | 0/74 | --- | 0/70 | ---
Burzotta, 2005 | Diver CE | Death | 1/48^§^ | 3/48 | --- | ---
Burzotta, 2005 | Control | | 2/48^§^ | 3/48 | --- | ---
Noel, 2005 | Export | Death | 1/48∥ | --- | --- | ---
Noel, 2005 | Control | | 2/48∥ | --- | --- | ---
Dudek, 2004 | Rescue System | Death | 0/24^¶^ | --- | --- | ---
Dudek, 2004 | Control | | 1/26^¶^ | --- | --- | ---

* 270-day data;

† 3-7 days post PCI in the both the groups together;

‡ 240-day data;

§ In the catheterization lab;

∥ Post-PCI;

¶ Time period not specified;

# 730-day data;

** 365-day data

Abbreviations: n=number; N=number of participants in the group; TAC=Thrombectomy Aspiration Catheter; TVAC=Transvascular aspiration catheter

Table 40 Mortality in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Migliorini, 2010 | AngioJet Rheolytic Thrombectomy | Death | --- | 4/256 | 7/251 | 7/221^*^
Migliorini, 2010 | Control | | --- | 7/245 | 11/242 | 14/220^*^
Ali, 2006 | AngioJet Catheter | Death independent of MACE at 30 days | --- | 11/240 | 14/24 | ---
Ali, 2006 | Control | Death at 6 months | --- | 2/240 | 5/240 | ---
Lefèvre, 2005 | X-Sizer Catheter | Death | --- | 4/100 | 6/100 | ---
Lefèvre, 2005 | Control | | --- | 4/101 | 4/101 | ---
Antoniucci, 2004 | AngioJet | Death | --- | 0/50 | --- | ---
Antoniucci, 2004 | Control | | --- | 0/50 | --- | ---
Napodano, 2003 | X-Sizer Catheter | Death | 3/46 | 3/46 | --- | ---
Napodano, 2003 | Control | | 3/46 | 3/46 | --- | ---

* 365-day data

Abbreviations: MACE=major adverse cardiac events; n=number; N=number of participants in the group

Table 41 Mortality in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Ito, 2010 | Filtrap | Death | --- | 0/19 | --- | ---
Ito, 2010 | Control | | --- | 1/17 | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | Death | --- | 8/312 | --- | 13/312^*^
Kelbæk, 2008 | Control | | --- | 8/314 | --- | 15/314^*^
Cura, 2007 | SpideRX | Death | --- | 4/70 | 5/70 | ---
Cura, 2007 | Control | | --- | 4/70 | 4/70 | ---
Guetta, 2007 | FilterWire EZ | Death | --- | 2/51 | --- | ---
Guetta, 2007 | Control | | --- | 0/49 | --- | ---
Lefèvre, 2004 | AngioGuardXP | Death | --- | 1/32 | --- | ---
Lefèvre, 2004 | Control | | --- | 1/28 | --- | ---

* 450 day data

Abbreviations: n=number; N=number of participants in the group

Table 42 Mortality in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | --- | ---
Duan, 2010 | Control | | --- | --- | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | --- | --- | --- | ---
Pan, 2010 | Control | | --- | --- | --- | ---
Tahk, 2008 | PercuSurge GuardWire | Death | --- | 0/54 | 0/54 | ---
Tahk, 2008 | Control | | --- | 2/52 | 2/52 | ---
Hahn, 2007 | GuardWire | Death | --- | --- | 0/19 | ---
Hahn, 2007 | Control | | --- | --- | 1/20 | ---
Matsuo, 2007 | GuardWire Distal Protection System | Cardiac death | --- | 1/80 | 1/80 | ---
Matsuo, 2007 | Control | | --- | 2/74 | 3/74 | ---
Muramatsu, 2007 | GuardWire Plus System | Death | 5/173 | 5/173 | 11/173 | ---
Muramatsu, 2007 | Control | | 7/168 | 7/168 | 11/168 | ---
Zhou, 2007 | PercuSurge GuardWire | --- | --- | --- | --- | ---
Zhou, 2007 | Control | | --- | --- | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | --- | ---
Okamura, 2005 | Control | | --- | --- | --- | ---
Stone, 2005 | GuardWire Plus | Death | --- | 5/246 | 8/243 | ---
Stone, 2005 | Control | | --- | 7/244 | 8/233 | ---

Abbreviations: n=number; N=number of participants in the group

Table 43 Mortality in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Haeck, 2009 | Proxis | Death | --- | 2/141 | 2/141 | ---
Haeck, 2009 | Control | | --- | 2/143 | 4/143 | ---

Abbreviations: n=number; N=number of participants in the group

Table 44 Mortality in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | Death | 1/30 | --- | --- | 1/30^*^
Parikh, 2008 | Distal Balloon Embolic Protection | Control | | --- | 1/37 | --- | 4/37^*^
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | Death | --- | 2/100 | 3/100 | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | | --- | 3/100 | 3/100 | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | Death | 2/129 | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | | 2/129 | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | Death | 0/24 | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | | 3/56 | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | Death | --- | 2/33 | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | | --- | 1/33 | --- | ---

* 730-day data

Abbreviations: n=number; N=number of participants in the group

Table 45 Mortality in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | --- | 0/15 | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | | --- | 0/16 | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 46 Mortality in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | Cardiac death | --- | 2/52 | --- | 2/50^*^
Sardella, 2008 | Catheter Aspiration | Export Medtronic | | --- | 3/51 | --- | 0/48^*^
Yan, 2007 | Catheter Aspiration | Diver CE catheter | Death | --- | 2/61 | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | | --- | 2/61 | --- | ---

* 365-day data

Abbreviations: n=number; N=number of participants in the group

Table 47 Mortality in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 48 Mortality in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | Death | --- | --- | 0/19 | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | | --- | --- | 0/14 | ---

Abbreviations: MtPA=mutant plasminogen activator; n=number; N=number of participants in the group

Table 49 Mortality in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | Death | --- | --- | 0/57 | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | | --- | --- | 0/63 | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 50 Mortality in observational studies

Study, Year | Device Category | Group | Mortality definition | In-hospital mortality n/N | 30-day mortality n/N | 180-day mortality n/N | 365-day mortality n/N
Beaudoin, 2010 | Catheter aspiration | Export | Death | --- | 8/164 | --- | 9/154
Beaudoin, 2010 | Catheter aspiration | Control | | | 16/370 | | 26/353
Kim, 2010 | Catheter Aspiration | Thrombus Aspiration | Death | 22/429 | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | | 19/429 | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | | --- | --- | --- | ---
Nilsen, 2009 * | Catheter Aspiration | Aspiration Catheter | Death | --- | 10/381 | --- | ---
Nilsen, 2009 * | Catheter Aspiration | Control | | --- | 70/2917 | --- | ---
Nilsen, 2009 * | Catheter Aspiration | Aspiration Catheter | Cardiac death | --- | 10/381 | --- | ---
Nilsen, 2009 * | Catheter Aspiration | Control | | --- | 64/2917 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^†^ | Death | --- | 37/990 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | | --- | 180/2923 | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | Death | 7/239 | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | | 55/1021 | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | Death | --- | --- | 10/200^‡^ | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | | --- | --- | 76/1168^‡^ | ---

* Data from a single study;

† Rescue Catheter, Thrombuster Catheter, Transvascular Aspiration Catheter, Export Catheter;

‡ 270-day data;

Abbreviations: n=number; N=number of participants in the group

Table 51 Myocardial infarction in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Dudek, 2010 | Diver CE | 0/100 | --- | 1/100 | ---
Dudek, 2010 | Control | 1/96 | --- | 3/96 | ---
Liistro, 2009 | Export Thrombectomy Catheter | --- | --- | 3/55 | ---
Liistro, 2009 | Control | --- | --- | 3/56 | --
Lipiecki, 2009 | Export Catheter | --- | --- | --- | ---
Lipiecki, 2009 | Control | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | ---
Moura, 2009 | Control | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | 0/88 | 0/88 | 0/88 | 0/88^*^
Sardella, 2009 | Control | 0/87 | 0/87 | 0/87 | 1/87^*^
Chao, 2008 | Export Aspiration Catheter | --- | --- | --- | ---
Chao, 2008 | Control | --- | --- | --- | ---
Chevalier, 2008 | Export Aspiration Catheter | --- | 2/120 | --- | ---
Chevalier, 2008 | Control | --- | 1/129 | --- | ---
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | ---
Ikari, 2008 | TVAC | 0/178 | --- | 0/170^†^ | ---
Ikari, 2008 | Control | 1/171 | --- | 1/158^†^ | ---
Svilaas, 2008 | 6F Export Aspiration Catheter | --- | 4/529 | --- | 12/535^‡^
Svilaas, 2008 | Control | --- | 10/531 | --- | 23/536^‡^
DeLuca, 2006 | Diver CE | --- | --- | 1/35 | ---
DeLuca, 2006 | Control | --- | --- | 0/38 | ---
Kaltoft, 2006 | Rescue Catheter | --- | 0/108 | --- | ---
Kaltoft, 2006 | Control | --- | 1/107 | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | ---
Lee, 2006 | Control | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | 0/74 | --- | 0/74 | ---
Silva-Orrego, 2006 | Control | 074 | --- | 1/7 | ---
Burzotta, 2005 | Diver CE | --- | 2/48 | --- | ---
Burzotta, 2005 | Control | --- | 2/48 | --- | ---
Noel, 2005 | Export | --- | --- | --- | ---
Noel, 2005 | Control | --- | --- | --- | ---
Dudek, 2004 | Rescue System | --- | --- | --- | ---
Dudek, 2004 | Control | --- | --- | --- | ---

* 730-day data;

† 240-day data;

‡ 365-day data;

Abbreviations: n=number; N=number of participants in the group; TAC=Thrombectomy Aspiration Catheter; TVAC=Transvascular aspiration catheter

Table 52 Myocardial infarction in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | --- | 2/256 | 2/251 | 2/22^*^
Migliorini, 2010 | Control | --- | 3/245 | 3/242 | 3/220^*^
Ali, 2006 | AngioJet Catheter | --- | 0/240 | --- | ---
Ali, 2006 | Control | --- | 0/240 | --- | ---
Lefèvre, 2005 | X-Sizer Catheter | --- | 1/100 | 2/100 | ---
Lefèvre, 2005 | Control | --- | 3/101 | 4/101 | ---
Antoniucci, 2004 | AngioJet | --- | 0/50 | --- | ---
Antoniucci, 2004 | Control | --- | 0/50 | --- | ---
Napodano, 2003 | X-Sizer Catheter | 0/46 | 2/46 | --- | ---
Napodano, 2003 | Control | 0/46 | 2/46 | --- | ---

* 365-day data

Abbreviations: n=number; N=number of participants in the group

Table 53 Myocardial infarction in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Ito, 2010 | Filtrap | --- | 0/19 | --- | ---
Ito, 2010 | Control | --- | 0/17 | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | --- | 5/312 | --- | 7/312^*^
Kelbæk, 2008 | Control | --- | 1/314 | --- | 3/314^*^
Cura, 2007 | SpideRX | --- | 0/70 | 0/70 | ---
Cura, 2007 | Control | --- | 5/70 | 5/70 | ---
Guetta, 2007 | FilterWire EZ | --- | 0/51 | --- | ---
Guetta, 2007 | Control | --- | 1/49 | --- | ---
Lefèvre, 2004 | AngioGuardXP | --- | 1/32 | --- | ---
Lefèvre, 2004 | Control | --- | 1/28 | --- | ---

* 450 day data

Abbreviations: n=number; N=number of participants in the group

Table 54 Myocardial infarction in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | ---
Duan, 2010 | Control | --- | --- | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | --- | --- | ---
Pan, 2010 | Control | --- | --- | --- | ---
Tahk, 2008 | PercuSurge GuardWire | --- | 1/54 | 1/54 | ---
Tahk, 2008 | Control | --- | 0/52 | 1/52 | ---
Hahn, 2007 | GuardWire | --- | --- | 0/19 | ---
Hahn, 2007 | Control | --- | --- | 1/20 | ---
Matsuo, 2007 | GuardWire Distal Protection System | --- | 1/80 | 1/80 | ---
Matsuo, 2007 | Control | --- | 0/74 | 0/74 | ---
Muramatsu, 2007 | GuardWire Plus System | 0/173 | 0/173 | 0/173 | ---
Muramatsu, 2007 | Control | 1/168 | 1/168 | 1/168 | ---
Zhou, 2007 | PercuSurge GuardWire | --- | --- | --- | ---
Zhou, 2007 | Control | --- | --- | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | ---
Okamura, 2005 | Control | --- | --- | --- | ---
Stone, 2005 | GuardWire Plus | --- | 5/246 | 6/243 | ---
Stone, 2005 | Control | --- | 7/244 | 9/233 | ---

Abbreviations: n=number; N=number of participants in the group

Table 55 Myocardial infarction in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Haeck, 2009 | Proxis | --- | 2/141 | 3/141 | ---
Haeck, 2009 | Control | --- | 3/143 | 3/143 | ---

Abbreviations: n=number; N=number of participants in the group

Table 56 Myocardial infarction in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | 1/30 | --- | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | 3/57 | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | --- | --- | 2/63 | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | --- | 0/100 | 0/100 | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | --- | 0/100 | 0/100 | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 57 Myocardial infarction in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | 0/15 | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | --- | 0/16 | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 58 Myocardial infarction in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | --- | 0/52 | --- | 1/50^*^
Sardella, 2008 | Catheter Aspiration | Export Medtronic | --- | 0/51 | --- | 1/48^*^
Yan, 2007 | Catheter Aspiration | Diver CE catheter | --- | 1/61 | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | --- | 0/61 | --- | ---

* 730-day data

Abbreviations: n=number; N=number of participants in the group

Table 59 Myocardial infarction in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 60 Myocardial infarction in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | --- | --- | 1/19 | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | --- | --- | 0/14 | ---

Abbreviations: MtPA= mutant plasminogen activator; n=number; N=number of participants in the group

Table 61 Myocardial infarction in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | 3/57 | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | --- | --- | 2/63 | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 62 Myocardial infarction in observational studies

Study, Year | Device Category | Group | In-hospital myocardial infarction n/N | 30-day myocardial infarction n/N | 180-day myocardial infarction n/N | 365-day myocardial infarction n/N
Beaudoin, 2010 | Catheter aspiration | Export | --- | 2/164 | --- | 6/154
Beaudoin, 2010 | Catheter aspiration | Control | --- | 2/370 | | 5/353
Kim, 2010 | Catheter Aspiration | Thrombus Aspiration | --- | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | --- | 5/381 | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | --- | 55/2917 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | 6/239 | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | 10/1021 | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | --- | 8/200 | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | --- | 25/1168 | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: n=number; N=number of participants in the group

Table 63 Stroke in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Dudek, 2008 | Diver CE | --- | --- | --- | ---
Dudek, 2008 | Control | --- | --- | --- | ---
Liistro, 2009 | Export Thrombectomy Catheter | --- | --- | --- | ---
Liistro, 2009 | Control | --- | --- | --- | ---
Lipiecki, 2009 | Export Catheter | --- | --- | --- | ---
Lipiecki, 2009 | Control | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | ---
Moura, 2009 | Control | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | 2/88 | --- | --- | ---
Sardella, 2009 | Control | 0/87 | --- | --- | ---
Chao, 2008 | Export Aspiration Catheter | --- | --- | --- | ---
Chao, 2008 | Control | --- | --- | --- | ---
Chevalier, 2008 | Export Aspiration Catheter | --- | 2/120 | --- | ---
Chevalier, 2008 | Control | --- | 0/129 | --- | ---
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | ---
Ikari, 2008 | TVAC | --- | --- | --- | ---
Ikari, 2008 | Control | --- | --- | --- | ---
Svilaas, 2008 | 6F Export Aspiration Catheter | --- | --- | --- | ---
Svilaas, 2008 | Control | --- | --- | --- | ---
DeLuca, 2006 | Diver CE | --- | --- | --- | ---
DeLuca, 2006 | Control | --- | --- | --- | ---
Kaltoft, 2006 | Rescue Catheter | --- | 2/108 | --- | ---
Kaltoft, 2006 | Control | --- | 0/107 | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | ---
Lee, 2006 | Control | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | --- | --- | 0/74 | ---
Silva-Orrego, 2006 | Control | --- | --- | 0/70 | ---
Burzotta, 2005 | Diver CE | --- | 1/48 | --- | ---
Burzotta, 2005 | Control | --- | 1/48 | --- | ---
Noel, 2005 | Export | --- | --- | --- | ---
Noel, 2005 | Control | --- | --- | --- | ---
Dudek, 2004 | Rescue System | --- | --- | --- | ---
Dudek, 2004 | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group; TAC=Thrombectomy Aspiration Catheter; TVAC=Transvascular aspiration catheter

Table 64 Stroke in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | --- | 0/256 | 1/251 | 2/221^*^
Migliorini, 2010 | Control | --- | 1/245 | 1/242 | 1/220^*^
Ali, 2006 | AngioJet Catheter | --- | 4/240 | --- | ---
Ali, 2006 | Control | --- | 2/240 | --- | ---
Lefèvre, 2005 | X-Sizer Catheter | --- | 2/100 | 2/100 | ---
Lefèvre, 2005 | Control | --- | 0/101 | 0/101 | ---
Antoniucci, 2004 | AngioJet | --- | 1/50 | --- | ---
Antoniucci, 2004 | Control | --- | 0/50 | --- | ---
Napodano, 2003 | X-Sizer Catheter | 0/46 | 0/46 | --- | ---
Napodano, 2003 | Control | 0/46 | 0/46 | --- | ---

* 365-day data

Abbreviations: n=number; N=number of participants in the group

Table 65 Stroke in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Ito, 2010 | Filtrap | --- | --- | --- | ---
Ito, 2010 | Control | --- | --- | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | --- | 3/312 | --- | ---
Kelbæk, 2008 | Control | --- | 2/314 | --- | ---
Cura, 2007 | SpideRX | --- | --- | --- | ---
Cura, 2007 | Control | --- | --- | --- | ---
Guetta, 2007 | FilterWire EZ | --- | --- | --- | ---
Guetta, 2007 | Control | --- | --- | --- | ---
Lefèvre, 2004 | AngioGuardXP | --- | --- | --- | ---
Lefèvre, 2004 | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 66 Stroke in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | ---
Duan, 2010 | Control | --- | --- | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | --- | --- | ---
Pan, 2010 | Control | --- | --- | --- | ---
Tahk, 2008 | PercuSurge GuardWire | --- | --- | --- | ---
Tahk, 2008 | Control | --- | --- | --- | ---
Hahn, 2007 | GuardWire | --- | --- | --- | ---
Hahn, 2007 | Control | --- | --- | --- | ---
Matsuo, 2007 | GuardWire Distal Protection System | --- | --- | --- | ---
Matsuo, 2007 | Control | --- | --- | --- | ---
Muramatsu, 2007 | GuardWire Plus System | --- | --- | --- | ---
Muramatsu, 2007 | Control | --- | --- | --- | ---
Zhou, 2007 | PercuSurge GuardWire | --- | --- | --- | ---
Zhou, 2007 | Control | --- | --- | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | ---
Okamura, 2005 | Control | --- | --- | --- | ---
Stone, 2005 | GuardWire Plus | --- | 0/246 | 2/243 | ---
Stone, 2005 | Control | --- | 4/244 | 4/233 | ---

Abbreviations: n=number; N=number of participants in the group

Table 67 Stroke in randomized controlled trials evaluating proximal balloon embolic protection versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Haeck, 2009 | Proxis | --- | 0/141 | 0/141 | ---
Haeck, 2009 | Control | --- | 1/143 | 2/143 | ---

Abbreviations: n=number; N=number of participants in the group

Table 68 Stroke in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | --- | 0/100 | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | --- | 0/100 | --- | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 69 Stroke in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 70 Stroke in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | --- | --- | --- | ---
Sardella, 2008 | Catheter Aspiration | Export Medtronic | --- | --- | --- | ---
Yan, 2007 | Catheter Aspiration | Diver CE catheter | --- | 0/61 | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | --- | 0/61 | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 71 Stroke in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 72 Stroke in studies with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | --- | --- | 0/19 | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | --- | --- | 0/14 | ---

Abbreviations: MtPA=mutant plasminogen activator; n=number; N=number of participants in the group

Table 73 Stroke in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 74 Stroke in observational studies

Study, Year | Device Category | Group | In-hospital stroke n/N | 30-day stroke n/N | 180-day stroke n/N | 365-day stroke n/N
Beaudoin, 2010 | Catheter aspiration | Export | --- | 0/164 | --- | 0/154
Beaudoin, 2010 | Catheter aspiration | Control | | 0/370 | | 2/353
Kim, 2010 | Catheter Aspiration | Thrombus Aspiration | --- | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | --- | 5/381 | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | --- | 12/2917 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | 1/239 | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | 5/1021 | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | --- | --- | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: n=number; N=number of participants in the group

Table 75 Target revascularization in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Dudek, 2010 | Diver CE | In-hospital: Re-PCI (TVR, TLR, non-infarct involved vessel or CABG) 180d: TLR | 2/100 | --- | 0/100 | ---
Dudek, 2010 | Control | | 1/96 | --- | 1/96 | ---
Liistro, 2009 | Export Thrombectomy Catheter | TLR | --- | --- | 4/55 | ---
Liistro, 2009 | Control | | --- | --- | 4/56 | ---
Lipiecki, 2009 | Export Catheter | --- | --- | --- | --- | ---
Lipiecki, 2009 | Control | --- | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | --- | ---
Moura, 2009 | Control | --- | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | TVR | --- | 0/88 | 5/87^*^ | 4/88^†^
Sardella, 2009 | Control | | --- | 0/87 | 0/88^*^ | 5/87^†^
Chao, 2008 | Export Aspiration Catheter | TVR | --- | --- | 3/37 | ---
Chao, 2008 | Control | | --- | --- | 4/37 | ---
Chevalier, 2008 | Export Aspiration Catheter | TLR+TVR | --- | 2/120 | --- | ---
Chevalier, 2008 | Control | | --- | 1/129 | --- | ---
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | --- | ---
Ikari, 2008 | TVAC | TLR | 0/178 | --- | 20/170^‡^ | ---
Ikari, 2008 | Control | | 1/171 | --- | 31/158^‡^ | ---
Svilaas, 2008 | 6F Export Aspiration Catheter | TVR | --- | 24/529 | --- | 60/535^§^
Svilaas, 2008 | Control | | --- | 31/531 | --- | 69/536^§^
DeLuca, 2006 | Diver CE | --- | --- | --- | --- | ---
DeLuca, 2006 | Control | --- | --- | --- | --- | ---
Kaltoft, 2006 | Rescue Catheter | --- | --- | --- | --- | ---
Kaltoft, 2006 | Control | --- | --- | --- | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | --- | ---
Lee, 2006 | Control | --- | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | TVR | 1/74 | --- | 1/74 | ---
Silva-Orrego, 2006 | Control | | 0/74 | --- | 2/70 | ---
Burzotta, 2005 | Diver CE | TLR | --- | 1/48 | --- | ---
Burzotta, 2005 | Control | | --- | 1/48 | --- | ---
Noel, 2005 | Export | --- | --- | --- | --- | ---
Noel, 2005 | Control | --- | --- | --- | --- | ---
Dudek, 2004 | Rescue System | --- | --- | --- | --- | ---
Dudek, 2004 | Control | --- | --- | --- | --- | ---

* 270-day data;

† 730-day data;

‡ 240-day data;

§ 365-day data;

Abbreviations: CABG=coronary artery bypass graft; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TAC=Thrombectomy Aspiration Catheter; TIMI=thrombolysis in myocardial infarction; TLR=target lesion revascularization; TVAC=Transvascular aspiration catheter; TVR=target vessel revascularization

Table 76 Target revascularization in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | TVR | --- | 2/256 | 18/251 | 22/221^*^
Migliorini, 2010 | Control | | --- | 6/245 | 32/242 | 32/220^*^
Ali, 2006 | AngioJet Catheter | TLR or sub-acute thrombosis | --- | 5/240 | --- | ---
Ali, 2006 | Control | | --- | 1/240 | --- | ---
Lefèvre, 2005 | X-Sizer Catheter | TVR | --- | 2/100 | 3/100 | ---
Lefèvre, 2005 | Control | | --- | 0/101 | 5/101 | ---
Antoniucci, 2004 | AngioJet | TVR | --- | 0/50 | --- | ---
Antoniucci, 2004 | Control | | --- | 0/50 | --- | ---
Napodano, 2003 | X-Sizer Catheter | TVR | 0/46 | 0/46 | --- | ---
Napodano, 2003 | Control | | 0/46 | 0/46 | --- | ---

* 365-day data

Abbreviations: n=number; N=number of participants in the group; TLR=target lesion revascularization; TVR=target vessel revascularization

Table 77 Target revascularization in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Ito, 2010 | Filtrap | TLR | --- | 0/19 | --- | ---
Ito, 2010 | Control | | --- | 0/17 | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | TLR | --- | 6/312 | --- | 39/312^*^
Kelbæk, 2008 | Control | | --- | 2/314 | --- | 22/314^*^
Cura, 2007 | SpideRX | Revascularization | --- | --- | 6/70 | ---
Cura, 2007 | Control | | --- | --- | 6/70 | ---
Guetta, 2007 | FilterWire EZ | --- | --- | --- | --- | ---
Guetta, 2007 | Control | --- | --- | --- | --- | ---
Lefèvre, 2004 | AngioGuardXP | --- | --- | --- | --- | ---
Lefèvre, 2004 | Control | --- | --- | --- | --- | ---

* 450 day data

Abbreviations: n=number; N=number of participants in the group; TLR=target lesion revascularization

Table 78 Target revascularization in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Tahk, 2008 | PercuSurge GuardWire | TVR | --- | 1/54 | 3/54 | ---
Tahk, 2008 | Control | | --- | 1/52 | 2/52 | ---
Hahn, 2007 | GuardWire | TLR | --- | --- | 0/19 | ---
Hahn, 2007 | Control | | --- | --- | 2/20 | ---
Matsuo, 2007 | GuardWire Distal Protection System | TVR | --- | --- | 5/80 | ---
Matsuo, 2007 | Control | | --- | --- | 9/74 | ---
Muramatsu, 2007 | GuardWire Plus System | TLR | 0/173 | 0/173 | 17/173 | ---
Muramatsu, 2007 | Control | | 1/168 | 1/168 | 16/168 | ---
Zhou, 2007 | PercuSurge GuardWire | --- | --- | --- | --- | ---
Zhou, 2007 | Control | | --- | --- | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | --- | ---
Okamura, 2005 | Control | | --- | --- | --- | ---
Stone, 2005 | GuardWire Plus | TVR | --- | 9/246 | 15/243 | ---
Stone, 2005 | Control | | --- | 6/244 | 13/233 | ---

Abbreviations: n=number; N=number of participants in the group; TLR=target lesion revascularization; TVR=target vessel revascularization

Table 79 Target revascularization in randomized controlled trials evaluating proximal balloon embolic protection device versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Haeck, 2009 * | Proxis | Urgent percutaneous TVR | --- | 2/141 | 6/141 | ---
Haeck, 2009 * | Control | | --- | 4/143 | 7/143 | ---
Haeck, 2009 * | Proxis | Urgent percutaneous TLR | --- | 2/141 | 5/141 | ---
Haeck, 2009 * | Control | | --- | 3/143 | 5/143 | ---
Haeck, 2009 * | Proxis | Surgical TVR | --- | 1/141 | 1/141 | ---
Haeck, 2009 * | Control | | --- | 2/143 | 3/143 | ---

* Data from the same study

Abbreviations: n=number; N=number of participants in the group; TLR=target lesion revascularization; TVR=target vessel revascularization

Table 80 Target revascularization in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | TVR | 0/30^*^ | --- | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | Revascularization | --- | 0/100 | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | | --- | 0/100 | --- | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | --- | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | 0/33 | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | --- | 1/33 | --- | --- | ---

* Within 3 days of index procedure

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TVR=target vessel revascularization

Table 81 Target revascularization in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | Revascularization | --- | 0/15 | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | | --- | 0/16 | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 82 Target revascularization in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | TVR | --- | 0/52 | --- | 3/50^*^
Sardella, 2008 | Catheter Aspiration | Export Medtronic | | --- | 0/51 | --- | 2/48^*^
Yan, 2007 | Catheter Aspiration | Diver CE catheter | TVR | --- | 1/61 | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | | --- | 1/61 | --- | ---

* 365-day data

Abbreviations: n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 83 Target revascularization in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | --- | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 84 Target revascularization in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | Re-intervention of IRA | --- | --- | 4/19 | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | | --- | --- | 4/14 | ---

Abbreviations: IRA=infarct related artery; MtPA=mutant plasminogen activator; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention

Table 85 Target revascularization in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | Re-PCI | --- | --- | 8/57 | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | | --- | --- | 8/63 | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 86 Target revascularization in observational studies

Study, Year | Device Category | Group | Target revascularization definition | In-hospital target revascularization n/N | 30-day target revascularization n/N | 180-day target revascularization n/N | 365-day target revascularization n/N
Beaudoin, 2010 | Catheter aspiration | Export | Any unplanned PCI performed for recurrent symptoms | --- | 4/164 | --- | 12/154
Beaudoin, 2010 | Catheter aspiration | Control | | | 7/370 | | 25/353
Kim, 2010 | Catheter Aspiration | Thrombus Aspiration | --- | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | TVR | --- | 7/381 | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | | --- | 73/2917 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical thrombectomy | AngioJet XMI or XVG Catheter | TVR | 5/239 | --- | --- | ---
Chinnaiyan, 2006 | Mechanical thrombectomy | Control | | 28/1021 | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | TVR | --- | --- | 11/200^†^ | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | | --- | --- | 56/1168^†^ | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter;

† 270-day data

Abbreviations: n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 87 Major adverse cardiac events in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Dudek, 2010 | Diver CE | Mortality, reinfarction, rePCI | 5/100 | --- | 5/100^§^ | ---
Dudek, 2010 | Control | | 5/96 | --- | 6/96^§^ | ---
Liistro, 2009 | Export Thrombectomy Catheter | --- | --- | --- | 8/55 | ---
Liistro, 2009 | Control | | --- | --- | 7/56 | ---
Lipiecki, 2009 | Export Catheter | --- | --- | --- | --- | ---
Lipiecki, 2009 | Control | | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | --- | ---
Moura, 2009 | Control | | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | Cardiac mortality, nonfatal reinfarction and TVR | 2/88^*^ | 0/88 | 4/88^†^ | 4/88^‡^
Sardella, 2009 | Control | | 1/87^*^ | 1/87 | 9/87^†^ | 12/87^‡^
Chevalier, 2008 | Export Aspiration Catheter | Mortality, reinfarction, emergent bypass surgery, TLR or CVA | --- | 7/120 | --- | ---
Chevalier, 2008 | Control | | --- | 6/129 | --- | ---
Chao, 2008 | Export Aspiration Catheter | Mortality, stroke, non fatal reinfarction, TVR | --- | --- | 5/37 | ---
Chao, 2008 | Control | | --- | --- | 10/37 | ---
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | --- | ---
Ciszewski, 2008 | Control | | --- | --- | --- | ---
Ikari, 2008 | TVAC | Mortality, recurrence of MI and TLR | 1/178 | --- | 22/170∥ | 36/180^#^
Ikari, 2008 | Control | | 2/171 | --- | 33/158∥ | 62/175^#^
Svilaas, 2008 | 6F Export Aspiration Catheter | Mortality, reinfarction or TVR | --- | 36/529 | --- | 89/535^**^
Svilaas, 2008 | Control | | --- | 50/531 | --- | 109/536^**^
DeLuca, 2006 | Diver CE | Mortality, new onset MI, and hospitalization for CHF | --- | --- | 3/35 | ---
DeLuca, 2006 | Control | | --- | --- | 4/38 | ---
Kaltoft, 2006 | Rescue Catheter | Mortality, reinfarction, disabling stroke | --- | 2/108 | --- | ---
Kaltoft, 2006 | Control | | --- | 2/107 | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | --- | ---
Lee, 2006 | Control | | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | --- | --- | --- | --- | ---
Silva-Orrego, 2006 | Control | | --- | --- | --- | ---
Burzotta, 2005 | Diver CE | Major adverse events | --- | 5/48 | --- | ---
Burzotta, 2005 | Control | | --- | 5/48 | --- | ---
Noel, 2005 | Export | --- | 1/24^††^ | --- | --- | ---
Noel, 2005 | Control | | 2/26^††^ | --- | --- | ---
Dudek, 2004 | Rescue System | --- | --- | --- | --- | ---
Dudek, 2004 | Control | | --- | --- | --- | ---

§ Reinfarction and mortality;

* Cardiac Mortality, non fatal reinfarction, TVR and stroke;

† 270-day data;

‡ 730-day data;

∥ 240-day data;

# 1095-day data;

** 365-day data;

†† no time period specified

Abbreviations: CHF=congestive heart failure; CVA=cerebrovascular accident; n=number; MACE=major adverse cardiac events; MI=myocardial infarction; N=number of participants in the group; PCI=percutaneous coronary intervention; TAC=Thrombectomy Aspiration Catheter; TLR=target lesion revascularization; TVAC=Transvascular aspiration catheter; TVR=target vessel revascularization

Table 88 Major adverse cardiac events in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | Mortality, MI, TVR, stroke | --- | 8/256 | 28/251 | 33/22^*^
Migliorini, 2010 | Control | | --- | 17/245 | 47/242 | 50/220^*^
Ali, 2006 | AngioJet Catheter | Mortality, new Q wave MI , emergent CABG, TLR, stroke, stent thrombosis | --- | 16/240 | --- | ---
Ali, 2006 | Control | | --- | 4/240 | --- | ---
Lefèvre, 2005 | X-Sizer Catheter | Major adverse cardiac and cerebral events | --- | 9/100 | 13/100 | ---
Lefèvre, 2005 | Control | | --- | 7/101 | 13/101 | ---
Antoniucci, 2004 | AngioJet | --- | --- | 0/50 | --- | ---
Antoniucci, 2004 | Control | | --- | 0/50 | --- | ---
Napodano, 2003 | X-Sizer Catheter | --- | --- | --- | --- | ---
Napodano, 2003 | Control | | --- | --- | --- | ---

* 365-day data

Abbreviations: CABG=coronary artery bypass graft; n=number; MACE=major adverse cardiac events; MI=myocardial infarction; N=number of participants in the group; TLR=target lesion revascularization; TVR=target vessel revascularization

Table 89 Major adverse cardiac events in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Ito, 2010 | Filtrap | Mortality,MI ,TLR | --- | 0/19 | --- | ---
Ito, 2010 | Control | | --- | 1/17 | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | Mortality, TLR, reinfarction, stroke | --- | 17/312 | 22/312^*^ | 59/312^†^
Kelbæk, 2008 | Control | | --- | 10/314 | 18/314^*^ | 40/314^†^
Cura, 2007 | SpideRX | Mortality, reinfarction, HF | --- | 10/70 | 10/70 | ---
Cura, 2007 | Control | | --- | 10/70 | 11/70 | ---
Guetta, 2007 | FilterWire EZ | Mortality, non fatal MI, CHF | --- | 3/51 | --- | ---
Guetta, 2007 | Control | | --- | 1/49 | --- | ---
Lefèvre, 2004 | AngioGuardXP | Mortality and MI | --- | 2/32 | --- | ---
Lefèvre, 2004 | Control | | --- | 2/28 | --- | ---

* 240-day data

† 450 day data

Abbreviations: CHF=congestive heart failure; HF=heart failure; MACE=major adverse cardiac events; MI=myocardial infarction; n=number; N=number of participants in the group; TLR=target lesion revascularization

Table 90 Major adverse cardiac events in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | --- | ---
Duan, 2010 | Control | | --- | --- | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | --- | --- | --- | ---
Pan, 2010 | Control | | --- | --- | --- | ---
Tahk, 2008 | PercuSurge GuardWire | Mortality, reinfarction and ischemia driven TVR | --- | 2/54 | 4/54 | ---
Tahk, 2008 | Control | | --- | 2/52 | 5/52 | ---
Hahn, 2007 | GuardWire | Mortality, MI and TLR | --- | --- | 0/19 | ---
Hahn, 2007 | Control | | --- | --- | 4/20 | ---
Matsuo, 2007 | GuardWire Distal Protection System | Mortality, non lethal MI, heart failure, ischemia-driven revascularization | --- | 3/80 | 10/80 | ---
Matsuo, 2007 | Control | | --- | 3/74 | 12/74 | ---
Muramatsu, 2007 | GuardWire Plus System | Mortality, myocardial infarction or TLR | 5/173 | 5/173 | 28/173 | ---
Muramatsu, 2007 | Control | | 9/168 | 9/168 | 28/168 | ---
Zhou, 2007 | PercuSurge GuardWire | --- | 0/52 | --- | --- | ---
Zhou, 2007 | Control | | 0/60 | --- | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | --- | ---
Okamura, 2005 | Control | | --- | --- | --- | ---
Stone, 2005 * | GuardWire Plus | MACE related to ischemic complications | --- | 14/246 | 24/243 | ---
Stone, 2005 * | Control | | --- | 18/244 | 26/233 | ---
Stone, 2005 * | GuardWire Plus | MACE related to LV dysfunction | --- | 36/246 | 40/243 | ---
Stone, 2005 * | Control | | --- | 32/244 | 35/233 | ---

* Data from a single study

Abbreviations: LV=left ventricular; MACE=major adverse cardiac events; MI=Myocardial infarction; n=number; N=number of participants in the group; TLR=target lesion revascularization; TVR=target vessel revascularization

Table 91 Major adverse cardiac events in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with St-segment elevation myocardial infarction

Study, Year | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Haeck, 2009 | Proxis | Mortality, spontaneous or procedural MI, stroke, percutaneous or surgical TVR | --- | 6/141 | 11/141 | ---
Haeck, 2009 | Control | Mortality, spontaneous or procedural MI, stroke, percutaneous or surgical TVR | --- | 10/143 | 15/143 | ---

Abbreviations: MACE=major adverse cardiac events; MI=myocardial infarction; n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 92 Major adverse cardiac events in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | --- | --- | --- | 13/100 | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | | --- | --- | 12/100 | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | 1/24 | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | | --- | --- | 7/56 | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | --- | 2/33 | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | | --- | 2/33 | --- | ---

Abbreviations: MACE=major adverse cardiac events; n=number; N=number of participants in the group

Table 93 Major adverse cardiac events in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | Mortality, recurrent MI, emergent CABG, repeat TVR | 9/77 | 9/77 | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | | 7/74 | 8/74 | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | | --- | --- | --- | ---

Abbreviations: CABG=coronary artery bypass graft; MACE=Major adverse cardiac events; MI=myocardial infarction; n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 94 Major adverse cardiac events in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | Cardiac mortality, Q and non Q wave MI, TVR | --- | 2/52 | --- | 5/50^*^
Sardella, 2008 | Catheter Aspiration | Export Medtronic | | --- | 3/51 | --- | 2/48^*^
Yan, 2007 | Catheter Aspiration | Diver CE catheter | Mortality, MI,TVR, stroke | --- | 4/61 | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | | --- | 3/61 | --- | ---

* 365-day data

Abbreviation: MACE=major adverse cardiac events; MI=myocardial infarction; n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 95 Major adverse cardiac events in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | | --- | --- | --- | ---

Abbreviations: MACE=major adverse cardiac events; n=number; N=number of participants in the group

Table 96 Major adverse cardiac events in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | --- | --- | --- | --- | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | | --- | --- | --- | ---

Abbreviations: MACE=major adverse cardiac events; MtPA=mutant plasminogen activator; n=number; N=number of participants in the group

Table 97 Major adverse cardiac events in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | | --- | --- | --- | ---

Abbreviations: MACE=major adverse cardiac events; n=number; N=number of participants in the group

Table 98 Major adverse cardiac events in observational studies

Study, Year | Device Category | Group | MACE definition | In-hospital MACE n/N | 30-day MACE n/N | 180-day MACE n/N | 365-day MACE n/N
Beaudoin, 2010 | Catheter aspiration | Export | Death, reinfarction, revascularization, stroke | --- | 14/164 | --- | 21/154
Beaudoin, 2010 | Catheter aspiration | Control | | | 25/370 | | 52/353
Kim, 2010 | Catheter Aspiration | Thrombus Aspiration | --- | --- | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | Mortality, re-infarction, TVR for ischemia, stroke | --- | 21/381 | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | | --- | 155/2917 | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | Mortality, re-infarction, TVR, stroke | 18/239 | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | | 92/1021 | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | Mortality, MI, TVR, stent thrombosis, stroke, peripheral vascular event | --- | --- | 28/200^†^ | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | | --- | --- | 136/1168^†^ | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter;

† 270-day data

Abbreviations: MACE=major adverse cardiac events; MI=myocardial infarction; n=number; N=number of participants in the group; TVR=target vessel revascularization

Table 99 ST-segment resolution in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Dudek, 2010 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Dudek, 2010 | Diver CE | 50/100 | --- | --- | 41/98 | --- | --- | --- | 52/96 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2010 | Control | 39/96 | --- | --- | 25/96 | --- | --- | --- | 34/96 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Liistro, 2009 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Liistro, 2009 | Export Thrombectomy Catheter | 39/55 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 39/55 | --- | --- | --- | --- | ---
Liistro, 2009 | Control | 22/56 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 22/56 | --- | --- | --- | --- | ---
Lipiecki, 2009 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Lipiecki, 2009 | Export Catheter | 11/19 | --- | --- | --- | --- | --- | --- | --- | --- | 3/19 | 5/19 | 11/19 | --- | 2/19^†^ | 2/19^†^ | 15/19^†^ | ---
Lipiecki, 2009 | Control | 11/24 | --- | --- | --- | --- | --- | --- | --- | --- | 6/21 | 4/21 | 11/21 | --- | 3/21^†^ | 7/21^†^ | 12/21^†^ | ---
Moura, 2009 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Moura, 2009 | TAC | 67/76 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 67/76^‡^ | ---
Moura, 2009 | Control | 33/76 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 33/76^‡^ | ---
Sardella, 2009 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Sardella, 2009 | Export Medtronic (EM) | 70/88 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 70/88 | --- | --- | --- | --- | ---
Sardella, 2009 | Control | 34/87 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 34/87 | --- | --- | --- | --- | ---
Chao, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Chao, 2008 | Export Aspiration Catheter | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Chao, 2008 | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Chevalier, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Chevalier, 2008 | Export Aspiration Catheter | 88/120 | --- | --- | --- | --- | --- | --- | --- | 88/120^§^ | --- | --- | --- | --- | --- | --- | --- | ---
Chevalier, 2008 | Control | 84/129 | --- | --- | --- | --- | --- | --- | --- | 88/129^§^ | --- | --- | --- | --- | --- | --- | --- | ---
Ciszewski, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ikari, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ikari, 2008 | TVAC | 37/115 | 39/115 | 39/115 | 37/115 | --- | --- | --- | --- | --- | --- | --- | --- | --- | 31/113^‖^ | 36/113^‖^ | 46/113^‖^ | ---
Ikari, 2008 | Control | 28/105 | 43/105 | 34/105 | 28/105 | --- | --- | --- | --- | --- | --- | --- | --- | --- | 25/105^‖^ | 39/105^‖^ | 41/105^‖^ | ---
Svilaas, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Svilaas, 2008 | 6F Export Aspiration Catheter | 275/486 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 61/486^¶^ | 150/486^¶^ | 275/486^¶^ | ---
Svilaas, 2008 | Control | 219/496 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 89/496^¶^ | 188/496^¶^ | 219/496^¶^ | ---
DeLuca, 2006 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
DeLuca, 2006 | Diver CE | 31/38 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 31/38 | --- | --- | --- | --- | ---
DeLuca, 2006 | Control | 21/38 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 21/38 | --- | --- | --- | --- | ---
Kaltoft, 2006 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Kaltoft, 2006 | Rescue Catheter | 37/93 | 43/97 | 32/97 | 22/97 | --- | --- | --- | --- | --- | 22/93 | 34/93 | 37/93 | --- | 16/80^#^ | 29/80^#^ | 35/80^#^ | ---
Kaltoft, 2006 | Control | 34/89 | 48/91 | 23/91 | 20/91 | --- | --- | --- | --- | --- | 25/89 | 30/89 | 34/89 | --- | 26/79^#^ | 24/79^#^ | 29/79^#^ | ---
Lee, 2006 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Lee, 2006 | Export Aspiration Catheter | 40/67 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 40/67^‡,§^
Lee, 2006 | Control | 24/66 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 24/66^‡,§^
Silva-Orrego, 2006 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Silva-Orrego, 2006 | Pronto Extraction Catheter | 50/74 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 3/74^‡^ | 21/74^‡^ | 50/74^‡^ | ---
Silva-Orrego, 2006 | Control | 37/74 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 10/74^‡^ | 27/74^‡^ | 37/74^‡^ | ---
Burzotta, 2005 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Burzotta, 2005 | Diver CE | 29/46 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 29/46^‡^ | ---
Burzotta, 2005 | Control | 18/49 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 18/49^‡^ | ---
Noel, 2005 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Noel, 2005 | Export | 12/24 | --- | --- | --- | --- | --- | --- | 12/24 | 21/24^§^ | --- | --- | --- | --- | --- | --- | --- | ---
Noel, 2005 | Control | 3/26 | --- | --- | --- | --- | --- | --- | 3/26 | 16/26^§^ | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2004 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Dudek, 2004 | Rescue System | 27/40 | --- | --- | --- | --- | 6/40 | 6/40 | 27/40 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2004 | Control | 8/32 | --- | --- | --- | --- | 8/32 | 16/32 | 8/32 | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† 24 hours after PCI;

‡ Post procedure, time period not specified;

§ >50% Resolution;

‖ 3-6 hours after PCI;

¶ 30-60 minutes after PCI;

# 6 hours after PCI

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution; TAC=Thrombectomy Aspiration Catheter; TVAC=Transvascular aspiration catheter

Table 100 ST-segment resolution in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Migliorini, 2010 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | 211/246 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 211/246^†,‡^
Migliorini, 2010 | Control | 189/240 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 189/240^†,‡^
Ali, 2006 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ali, 2006 | AngioJet Catheter | 105/176 | --- | --- | --- | --- | --- | --- | --- | --- | 21/176^§^ | 50/176^§^ | 105/176^§^ | 136/176^§,‡^ | --- | --- | --- | ---
Ali, 2006 | Control | 111/164 | --- | --- | --- | --- | --- | --- | --- | --- | 18/164^§^ | 35/164^§^ | 130/164^§^ | 130/164^§,‡^ | --- | --- | --- | ---
Lefèvre, 2005 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Lefèvre, 2005 | X-Sizer Catheter | 61/90 | --- | --- | --- | --- | --- | --- | --- | 61/90^‡^ | --- | --- | --- | --- | --- | --- | --- | ---
Lefèvre, 2005 | Control | 50/95 | --- | --- | --- | --- | --- | --- | --- | 50/95^‡^ | --- | --- | --- | --- | --- | --- | --- | ---
Antoniucci, 2004 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Antoniucci, 2004 | AngioJet | 45/50 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 45/50^†,‡^
Antoniucci, 2004 | Control | 36/50 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 36/50^†,‡^
Napodano, 2003 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Napodano, 2003 | X-Sizer Catheter | 38/46 | --- | --- | --- | --- | --- | --- | --- | 38/46^‡^ | --- | --- | --- | --- | --- | --- | --- | ---
Napodano, 2003 | Control | 24/46 | --- | --- | --- | --- | --- | --- | --- | 24/46^‡^ | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† 30 minutes after PCI;

‡ >50% Resolution;

§ 90 minutes (allowed up to 180 minutes) after PCI

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 101 ST-segment resolution in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Ito, 2010 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ito, 2010 | Filtrap | 9/19 | --- | --- | --- | --- | --- | --- | 9/19 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ito, 2010 | Control | 4/17 | --- | --- | --- | --- | --- | --- | 4/17 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kelbæk, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | 230/302 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 230/302 | 211/302^†^ | --- | --- | --- | ---
Kelbæk, 2008 | Control | 218/301 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 218/301 | 198/301^†^ | --- | --- | --- | ---
Cura, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Cura, 2007 | SpideRX | 43/70 | --- | --- | --- | --- | --- | --- | 43/70 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Cura, 2007 | Control | 42/70 | --- | --- | --- | --- | --- | --- | 42/70 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Guetta, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Guetta, 2007 | FilterWire EZ | 33/51 | --- | --- | --- | --- | 5/51 | 13/51 | 33/51 | --- | 0/51 | 18/51 | 33/51 | --- | --- | --- | --- | ---
Guetta, 2007 | Control | 32/49 | --- | --- | --- | --- | 5/49 | 12/49 | 32/49 | --- | 2/49 | 13/49 | 35/49 | --- | --- | --- | --- | ---
Lefèvre, 2004 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Lefèvre, 2004 | AngioGuardXP | 20/30 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 20/30^‡^ | 24/30^‡,§^
Lefèvre, 2004 | Control | 14/26 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 14/26^‡^ | 19/26^‡,§^

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† 100% Resolution;

‡ Post procedure, time period not specified;

§ >50% Resolution

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 102 ST-segment resolution in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Duan, 2010 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Duan, 2010 | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Pan, 2010 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Pan, 2010 | PercuSurge Guardwire | 61/90 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Pan, 2010 | Control | 50/95 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Tahk, 2008 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Tahk, 2008 | PercuSurge GuardWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Tahk, 2008 | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Hahn, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Hahn, 2007 | GuardWire | 16/19 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 16/19^‡^ | --- | --- | --- | 15/19^†,‡^
Hahn, 2007 | Control | 9/20 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 9/20^‡^ | --- | --- | --- | 12/20^†,‡^
Matsuo, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Matsuo, 2007 | GuardWire Distal Protection System | 41/80 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 41/80^§^ | ---
Matsuo, 2007 | Control | 39/74 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 39/74^§^ | ---
Muramatsu, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Muramatsu, 2007 | GuardWire Plus System | 66/173 | --- | --- | --- | --- | --- | --- | --- | --- | 52/173 | 55/173 | 66/173 | --- | 46/173 | 49/173 | 78/173 | ---
Muramatsu, 2007 | Control | 60/168 | --- | --- | --- | --- | --- | --- | --- | --- | 56/168 | 52/168 | 60/168 | --- | 42/168 | 53/168 | 73/168 | ---
Zhou, 2007 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Zhou, 2007 | PercuSurge GuardWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Zhou, 2007 | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Okamura, 2005 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Okamura, 2005 | PercuSurge | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Okamura, 2005 | GuardWire Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Stone, 2005 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Stone, 2005 | GuardWire Plus | 152/240 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 152/240 | ---
Stone, 2005 | Control | 148/239 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 148/239 | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† 180 minutes after PCI;

‡ >50% Resolution;

§ 30 minutes after PCI

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 103 ST-segment resolution in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patient with ST-segment elevation myocardial infarction

Study, Year | Group | CompositeSTSR Definition^*^(n/N) | Immediately after PCI(n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Haeck, 2009 | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Haeck, 2009 | Proxis | 101/126 | --- | --- | 85/129 | --- | --- | --- | 101/126 | --- | --- | --- | 100/124 | --- | --- | --- | 96/130^†^ | 98/126^‡^
Haeck, 2009 | Control | 93/129 | --- | --- | 97/131 | --- | --- | --- | 93/129 | --- | --- | --- | 97/131 | --- | --- | --- | 87/135^†^ | 100/131^‡^

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† 30 minutes after PCI;

‡ ≥70 % at 120 minutes after PCI

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 104 ST-segment resolution in randomized controlled trials evaluating thrombectomy or distal protection devices versus control in mixed acute coronary syndromes population

Study, Year | Device Category | Group | Composite STSR Definition^*^(n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Parikh, 2008 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Gick, 2005 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Sardella, 2005 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kunii, 2004 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nanasato, 2004 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | 27/34^†^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | 15/30^†^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Matsushita, 2003 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Beran, 2002 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Beran, 2002 | Mechanical Thrombectomy | X-sizer | 19/23 | --- | --- | --- | 19/23^‡^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | 12/23 | --- | --- | --- | 12/23^‡^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† Éarly ST- segment resolution;

‡ >50% Resolution

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 105 ST-segment resolution in randomized controlled trials evaluating thrombectomy or distal protection devices versus control in unstable angina or non- ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Webster, 2008 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2003 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 106 ST-segment resolution in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Sardella, 2008 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | 34/52 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 34/52 | --- | --- | --- | --- | ---
Sardella, 2008 | Catheter Aspiration | Export Medtronic | 42/51 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 42/51 | --- | --- | --- | --- | ---
Yan, 2007 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Yan, 2007 | Catheter Aspiration | Diver CE catheter | 35/61 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 35/61^†^ | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | 36/61 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | 36/61^†^ | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† Measured immediately, 90 minutes and 6 hours

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 107 ST-segment resolution in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Wita, 2009 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Wita, 2009 | Catheter Aspiration | Diver CE | 10/19 | --- | --- | --- | --- | --- | --- | --- | 10/19^†^ | --- | --- | --- | --- | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | 13/19 | --- | --- | --- | --- | --- | --- | --- | 13/23^†^ | --- | --- | --- | --- | --- | --- | --- | ---
Ozaki, 2006 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† >50% Resolution

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 108 ST-segment resolution in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Yamamoto, 2006 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes

Abbreviations: MtPA=Mutant Plasminogen Activator; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 109 ST-segment resolution in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Ochala, 2007 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | 29/57 | --- | --- | --- | --- | 12/57 | 16/57 | 29/57 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | 25/63 | --- | --- | --- | --- | 19/63 | 19/63 | 25/63 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kanaya, 2003 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy +Stenting +Distal Protection Device | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 110 ST-segment resolution in observational studies

Study, Year | Device Category | Group | Composite STSR Definition^*^ (n/N) | Immediately after PCI (n/N) | | | | 60 minutes after PCI | | | | 90 minutes after PCI | | | | Other Times after PCI
Beaudoin, 2010 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Beaudoin, 2010 | Catheter aspiration | Export | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Beaudoin, 2010 | Catheter aspiration | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kim, 2010 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Kim, 2010 | Catheter Aspiration | Thrombus aspiration | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kim, 2010 | Catheter Aspiration | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ko, 2009 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nilsen, 2009 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | 153/318 | --- | --- | --- | --- | --- | --- | 153/318 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | 1466/2915 | --- | --- | --- | --- | --- | --- | 1466/2915 | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nakatani, 2007 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Nakatani, 2007 | Catheter Aspiration | Multiple devices^†^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Chinnaiyan, 2006 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Simonton, 2006 | | | | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others | <30% | 30-70% | >70% | Others
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Composite STSR: >70% at 60 minutes, if this is unavailable, >70% at 90 minutes or 30 minutes after PCI, if 70% is unavailable, >50% at 60 minutes;

† Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; STSR=ST-segment resolution

Table 111 Ejection fraction of randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | n | Time EF Measured | Mean EF (SD) | P-value
Yamamoto, 2006 * | Catheter Aspiration | Thrombuster+MtPA | 17 | 1-3d | 53 (12) | 0.31
Yamamoto, 2006 * | Catheter Aspiration | Thrombuster | 16 | | 48 (12)
Yamamoto, 2006 * | Catheter Aspiration | Thrombuster+MtPA | 18 | 180d | 59 (8) | 0.57
Yamamoto, 2006 * | Catheter Aspiration | Thrombuster | 12 | | 56 (10)

* Data from a single study;

† Mutant Plasminogen Activator

Abbreviations: d=days; EF=ejection fraction; MtPA=mutant plasminogen activator; n=number of participants included in the analysis of ejection fraction; SD=standard deviation

Table 112 Ejection fraction in observational studies

Study, Year | Device Category | Group | n | Time EF Measured | Mean EF (SD) | P-value
Beaudoin, 2010 | Catheter aspiration | Export | --- | --- | --- | ---
Beaudoin, 2010 | Catheter aspiration | Control | ---
Kim, 2010 | Catheter aspiration | Thrombus aspiration | 429 | Post-PCI | 49 (11) | 0.0005
Kim, 2010 | Catheter aspiration | Control | 429 | | 53 (11)
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | --- | | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | | ---
Chinnaiyan, 2006 | Mechanical thrombectomy | AngioJet XMI or XVG Catheter | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical thrombectomy | Control | --- | | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: EF=ejection fraction; n=number of participants included in the analysis of ejection fraction; PCI=percutaneous coronary intervention; SD=standard deviation

Table 113 Intermediate health outcomes in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Dudek, 2010 | Diver CE | 67/88 | 86/98 | --- | 10/98
Dudek, 2010 | Control | 48/83 | 78/96 | --- | 17/96
Liistro, 2009 | Export Thrombectomy Catheter | 51/55^*^ | 53/55 | 4/55 | 2/55
Liistro, 2009 | Control | 40/56^*^ | 46/56 | 14/56 | 10/56
Lipiecki, 2009 | Export Catheter | 6/20^*^ | --- | 2/20 | ---
Lipiecki, 2009 | Control | 7/20^*^ | --- | 3/24 | ---
Moura, 2009 | TAC | 68/75^*^ | --- | --- | ---
Moura, 2009 | Control | 47/76^*^ | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | 62/88 | 88/88 | --- | ---
Sardella, 2009 | Control | 25/87 | 86/87 | --- | ---
Chao, 2008 | Export Aspiration Catheter | --- | --- | --- | ---
Chao, 2008 | Control | --- | --- | --- | ---
Chevalier, 2008 | Export Aspiration Catheter | 43/120 | 98/120 | 11/120 | 4/120
Chevalier, 2008 | Control | 33/129 | 99/129 | 22/129 | 13/129
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | ---
Ikari, 2008 | TVAC | 82/178 | 156/178 | 28/178 | 22/178^†^
Ikari, 2008 | Control | 35/171 | 138/171 | 50/171 | 33/171^†^
Svilaas, 2008 | 6F Export Aspiration Catheter | 224/490 | 431/501 | --- | ---
Svilaas, 2008 | Control | 158/490 | 409/496 | --- | ---
DeLuca, 2006 | Diver CE | 14/38 | 30/38 | --- | ---
DeLuca, 2006 | Control | 5/38 | 26/38 | --- | ---
Kaltoft, 2006 | Rescue Catheter | --- | 93/104 | 9/104 | ---
Kaltoft, 2006 | Control | --- | 91/104 | 6/105 | ---
Lee, 2006 | Export Aspiration Catheter | 16/67 | --- | 6/67 | 5/67
Lee, 2006 | Control | 8/66 | --- | 2/66 | 3/66
Silva-Orrego, 2006 | Pronto Extraction Catheter | 65/74 | 66/74 | 4/74 | 2/74
Silva-Orrego, 2006 | Control | 32/74 | 58/74 | 14/74 | 11/74
Burzotta, 2005 | Diver CE | 21/50 | 41/50 | 4/50 | 4/48
Burzotta, 2005 | Control | 11/49 | 34/49 | 8/49 | 6/49
Noel, 2005 | Export | --- | 23/24 | --- | 2/24^‡^
Noel, 2005 | Control | --- | 21/26 | --- | 7/26^‡^
Dudek, 2004 | Rescue System | 22/40 | 30/35 | --- | ---
Dudek, 2004 | Control | 12/32 | 28/32 | --- | ---

* MBG≥2;

† TIMI<3;

‡ Slow flow/no reflow/distal embolization

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TAC=Thrombectomy Aspiration Catheter; TIMI=thrombolysis in myocardial infarction; TVAC=Transvascular aspiration catheter

Table 114 Intermediate health outcomes in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | 155/215 | 203/252 | --- | ---
Migliorini, 2010 | Control | 167/211 | 207/241 | --- | ---
Ali, 2006 | AngioJet Catheter | 63/234 | 213/234 | 10/234 | 6/234
Ali, 2006 | Control | 75/235 | 228/235 | 12/235 | 5/235
Lefèvre, 2005 | X-Sizer Catheter | 29/92 | 93/97 | 2/97 | 3/97
Lefèvre, 2005 | Control | 28/91 | 89/100 | 10/100 | 10/100
Antoniucci, 2004 | AngioJet | --- | --- | --- | ---
Antoniucci, 2004 | Control | --- | --- | --- | ---
Napodano, 2003 | X-Sizer Catheter | 33/46 | 43/46 | 2/46 | 1/46
Napodano, 2003 | Control | 17/46 | 44/46 | 7/46 | 5/46

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 115 Intermediate health outcomes in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Ito, 2010 | Filtrap | --- | 17/19 | --- | ---
Ito, 2010 | Control | --- | 13/17 | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | --- | 295/312 | --- | ---
Kelbæk, 2008 | Control | --- | 268/314 | --- | ---
Cura, 2007 | SpideRX | --- | 29/32 | --- | 1/32^*^
Cura, 2007 | Control | --- | 27/28 | --- | 3/28^*^
Guetta, 2007 | FilterWire EZ | 47/70 | 55/70 | 5/70 | 2/70
Guetta, 2007 | Control | 59/70 | 60/70 | 8/70 | 2/70
Lefèvre, 2004 | AngioGuardXP | 33/49 | 43/49 | --- | ---
Lefèvre, 2004 | Control | 32/48 | 45/48 | --- | ---

* Slow flow/no reflow/distal embolization

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 116 Intermediate health outcomes in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Duan, 2010 | PercuSurge Guardwire Plus | --- | 44/46 | --- | ---
Duan, 2010 | Control | --- | 39/50 | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | 46/52 | --- | ---
Pan, 2010 | Control | --- | 36/52 | --- | ---
Tahk, 2008 | PercuSurge GuardWire | 39/60 | 58/60 | --- | ---
Tahk, 2008 | Control | 20/56 | 43/56 | --- | ---
Hahn, 2007 | GuardWire | 6/19 | 18/19 | 4/19 | 1/19
Hahn, 2007 | Control | 5/20 | 19/20 | 6/20 | 1/20
Matsuo, 2007 | GuardWire Distal Protection System | 46/80 | 64/80 | 5/80 | 3/80
Matsuo, 2007 | Control | 32/74 | 56/74 | 4/74 | 2/74
Muramatsu, 2007 | GuardWire Plus System | 42/167 | 133/173 | 4/173 | 2/173
Muramatsu, 2007 | Control | 32/158 | 131/168 | 7/168 | 6/168
Zhou, 2007 | PercuSurge GuardWire | 34/52 | 50/52 | --- | ---
Zhou, 2007 | Control | 20/60 | 48/60 | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | 8/8 | --- | ---
Okamura, 2005 | Control | --- | 8/8 | --- | ---
Stone, 2005 | GuardWire Plus | 138/226 | 219/239 | 22/237 | 1/238
Stone, 2005 | Control | 120/227 | 215/241 | 14/242 | 6/242

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 117 Intermediate health outcomes in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Haeck, 2009 | Proxis | 113/141 | 131/141 | 14/141 | ---
Haeck, 2009 | Control | 117/143 | 125/143 | 20/143 | ---

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 118 Intermediate health outcomes in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | 24/30 | 26/30 | 0/30 | 9/30
Parikh, 2008 | Distal Balloon Embolic Protection | Control | 5/37 | 18/37 | --- | 31/37
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | 64/100^*^ | 93/100 | 3/100 | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | 67/100^*^ | 93/100 | 8/100
Sardella, 2005 | Catheter Aspiration | Diver CE | 11/28 | 24/28 | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | 3/34 | 21/34 | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | 121/129 | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | 119/129 | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | 24/34 | 34/34 | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | 11/30 | 28/30 | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | 27/30 | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | --- | 26/31 | --- | ---

* MBG>1

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 119 Intermediate health outcomes in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | 72/77 | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | 70/74 | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | 15/15 | 3/15 | 0/15
Dudek, 2003 | Distal Filter Embolic Protection | Control | --- | 16/16 | --- | 0/16

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 120 Intermediate health outcomes in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | 16/52 | 38/52 | --- | ---
Sardella, 2008 | Catheter Aspiration | Export Medtronic | 22/51 | 42/51 | --- | ---
Yan, 2007 | Catheter Aspiration | Diver CE catheter | 43/61 | 58/61 | --- | 5/61^*^
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | 44/61 | 59/61 | --- | 4/61^*^

* Slow flow/no reflow/distal embolization

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 121 Intermediate health outcomes in randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Wita, 2009 | Catheter Aspiration | Diver CE | 12/19 | 19/19 | --- | ---
Wita, 2009 | Catheter Aspiration | Control | 14/23 (MBG 2-3) | 23/23 | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems PercuSurge GuardWire | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 122 Intermediate health outcomes in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | 13/23 | 22/23 | --- | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | 3/21 | 18/21 | --- | ---

Abbreviations: MBG=myocardial blush grade; MtPA=mutant plasminogen activator; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 123 Intermediate health outcomes in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | 34/55 | 51/57 | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | 38/58 | 56/63 | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | 26/30 | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | 20/30 | --- | ---

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 124 Intermediate health outcomes in observational studies

Study, Year | Device Category | Group | Post-PCI MBG-3 (n/N) | Post-PCI TIMI-3 (n/N) | Distal Embolization (n/N) | No reflow (n/N)
Beaudoin, 2010 | Catheter aspiration | Export | --- | 147/165 | --- | ---
Beaudoin, 2010 | Catheter aspiration | Control | --- | 324/370 | --- | ---
Kim, 2010 | Catheter aspiration | Thrombus aspiration | --- | 379/429 | --- | ---
Kim, 2010 | Catheter aspiration | Control | --- | 371/429 | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | --- | --- | 29/318 | ---
Nilsen, 2009 | Catheter Aspiration | Control | --- | --- | 93/2915 | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | --- | 205/239 | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | --- | 922/1021 | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | 170/200 | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | 1086/1168 | --- | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: MBG=myocardial blush grade; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; TIMI=thrombolysis in myocardial infarction

Table 125 Adverse outcomes in randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Dudek, 2010 | Diver CE | --- | --- | --- | ---
Dudek, 2010 | Control | --- | --- | --- | ---
Liistro, 2009 | Export Thrombectomy Catheter | --- | --- | --- | ---
Liistro, 2009 | Control | --- | --- | --- | ---
Lipiecki, 2009 | Export Catheter | --- | --- | --- | ---
Lipiecki, 2009 | Control | --- | --- | --- | ---
Moura, 2009 | TAC | --- | --- | --- | ---
Moura, 2009 | Control | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | --- | --- | --- | ---
Sardella, 2009 | Control | --- | --- | --- | ---
Chao, 2008 | Export Aspiration Catheter | 0/37 | --- | --- | ---
Chao, 2008 | Control | 1/37 | --- | --- | ---
Chevalier, 2008 | Export Aspiration Catheter | --- | --- | 1/120 | 2/120
Chevalier, 2008 | Control | --- | --- | 0/129 | 2/129
Ciszewski, 2008 | Rescue/Diver | --- | --- | --- | ---
Ciszewski, 2008 | Control | --- | --- | --- | ---
Ikari, 2008 | TVAC | 4/178 | 0/178 | --- | ---
Ikari, 2008 | Control | 15/171 | 0/171 | --- | ---
Svilaas, 2008 | 6F Export Aspiration Catheter | 0/502 | --- | --- | 5/502
Svilaas, 2008 | Control | 0/503 | --- | --- | 4/503
DeLuca, 2006 | Diver CE | 1/38 | --- | --- | ---
DeLuca, 2006 | Control | 0/38 | --- | --- | ---
Kaltoft, 2006 | Rescue Catheter | --- | --- | --- | ---
Kaltoft, 2006 | Control | --- | --- | --- | ---
Lee, 2006 | Export Aspiration Catheter | --- | --- | --- | ---
Lee, 2006 | Control | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | 0/74 | --- | --- | ---
Silva-Orrego, 2006 | Control | 4/74 | --- | --- | ---
Burzotta, 2005 | Diver CE | --- | --- | --- | ---
Burzotta, 2005 | Control | --- | --- | --- | ---
Noel, 2005 | Export | --- | --- | --- | ---
Noel, 2005 | Control | --- | --- | --- | ---
Dudek, 2004 | Rescue System | --- | --- | --- | ---
Dudek, 2004 | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group; TAC=Thrombectomy Aspiration Catheter; TVAC=Transvascular aspiration catheter

Table 126 Adverse outcomes in randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | --- | 0/256 | --- | ---
Migliorini, 2010 | Control | --- | 1/245 | --- | ---
Ali, 2006 | AngioJet Catheter | 9/234 | 2/234 | 1/234 | ---
Ali, 2006 | Control | 6/235 | 1/235 | 2/235
Lefèvre, 2005 | X-Sizer Catheter | --- | 0/100 | --- | ---
Lefèvre, 2005 | Control | --- | --- | --- | ---
Antoniucci, 2004 | AngioJet | --- | --- | --- | ---
Antoniucci, 2004 | Control | --- | --- | --- | ---
Napodano, 2003 | X-Sizer Catheter | --- | --- | --- | 1/46
Napodano, 2003 | Control | --- | --- | --- | 1/46

Abbreviations: n=number; N=number of participants in the group

Table 127 Adverse outcomes in randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Ito, 2010 | Filtrap | --- | --- | --- | ---
Ito, 2010 | Control | --- | --- | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | --- | --- | --- | ---
Kelbæk, 2008 | Control | --- | --- | --- | ---
Cura, 2007 | SpideRX | 0/70 | 0/70 | 0/70 | 0/70
Cura, 2007 | Control | 0/70 | 0/70 | 0/70 | 1/70
Guetta, 2007 | FilterWire EZ | --- | --- | --- | ---
Guetta, 2007 | Control | --- | --- | --- | ---
Lefèvre, 2004 | AngioGuardXP | --- | --- | --- | ---
Lefèvre, 2004 | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 128 Adverse outcomes in randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Duan, 2010 | PercuSurge Guardwire Plus | --- | --- | --- | ---
Duan, 2010 | Control | --- | --- | --- | ---
Pan, 2010 | PercuSurge Guardwire | --- | --- | --- | ---
Pan, 2010 | Control | --- | --- | --- | ---
Tahk, 2008 | PercuSurge GuardWire | --- | --- | --- | ---
Tahk, 2008 | Control | --- | --- | --- | ---
Hahn, 2007 | GuardWire | --- | --- | --- | ---
Hahn, 2007 | Control | --- | --- | --- | ---
Matsuo, 2007 | GuardWire | --- | --- | --- | 2/80
Matsuo, 2007 | Control | --- | --- | --- | 1/74
Muramatsu, 2007 | GuardWire Plus | --- | --- | --- | ---
Muramatsu, 2007 | Control | --- | --- | --- | ---
Zhou, 2007 | PercuSurge GuardWire | 0/52 | 0/52 | --- | ---
Zhou, 2007 | Control | 0/60 | 0/60 | --- | ---
Okamura, 2005 | PercuSurge GuardWire | --- | --- | --- | ---
Okamura, 2005 | Control | --- | --- | --- | ---
Stone, 2005 | GuardWire | --- | 2/229 | 11/238 | 34/238
Stone, 2005 | Control | --- | 0/234 | 6/242 | 38/242

Abbreviations: n=number; N=number of participants in the group

Table 129 Adverse outcomes in randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Haeck, 2009 | Proxis | --- | --- | --- | ---
Haeck, 2009 | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 130 Adverse outcomes in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | --- | --- | 0/30 | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | --- | --- | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Control | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 131 Adverse outcomes in randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 132 Adverse outcomes in direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Sardella, 2008 | Catheter Aspiration | Diver Invatec catheter | 0/52 | 0/52 | --- | ---
Sardella, 2008 | Catheter Aspiration | Export Medtronic | 1/51 | 0/51 | --- | ---
Yan, 2007 | Catheter Aspiration | Diver CE catheter | --- | --- | --- | ---
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 133 Adverse outcomes in randomized controlled trials with selective inclusion/exclusion criteria in patient with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Wita, 2009 | Catheter Aspiration | Diver CE | --- | --- | --- | ---
Wita, 2009 | Catheter Aspiration | Control | --- | --- | --- | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | --- | --- | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group

Table 134 Adverse outcomes in randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | --- | --- | --- | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | --- | --- | --- | ---

Abbreviations: MtPA=mutant plasminogen activator; n=number; N=number of participants in the group

Table 135 Adverse outcomes in randomized controlled trials with unique comparison in patients with mixed acute coronary syndromes

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | --- | --- | --- | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy+ Stenting | --- | --- | --- | ---

Abbreviations: n=number; N=number of participants in the group; vs=versus

Table 136 Adverse outcomes in observational studies

Study, Year | Device Category | Group | Coronary dissection (n/N) | Perforation (n/N) | Vessel spasm (n/N) | Side branch closure (n/N)
Beaudoin, 2010 | Catheter Aspiration | Export | --- | --- | --- | ---
Beaudoin, 2010 | Catheter Aspiration | Control | --- | --- | --- | ---
Kim, 2010 | Catheter aspiration | Thrombus aspiration | --- | --- | --- | ---
Kim, 2010 | Catheter aspiration | Control | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | 21/318 | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | 154/2915 | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | --- | 0/239 | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | --- | 2/1021 | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | --- | --- | --- | ---

* Rescue Catheter, Trombuster Catheter, Transvascular Aspiration Catheter, Export Catheter

Abbreviations: n=number; N=number of participants in the group

Table 137 Impact of catheter aspiration devices versus control on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 8.08 | 0.70 (0.47 to 1.03) | 0%
Myocardial infarction | 8.80 | 0.61 (0.36 to 1.04) | 0%
Stroke | 0.79 | 3.18 (0.73 to 13.88) | 0%
Target revascularization | 9.48 | 0.79 (0.61 to 1.02) | 0%
MACE | 12.66 | 0.73 (0.61 to 0.88) | 0%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 138 Impact of mechanical thrombectomy devices versus control on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 7.80 | 1.19 (0.51 to 2.76) | 54.9
Myocardial infarction | 8.98 | 0.71 (0.27 to 1.85) | 0%
Stroke | 5.79 | 2.42 (0.75 to 7.78) | 0%
Target revascularization | 6.22 | 0.87 (0.36 to 2.10) | 39.2%
MACE | 6.22 | 1.23 (0.50 to 3.01) | 79.9%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 139 Impact of distal filter embolic protection devices versus control on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 11.49 | 0.97 (0.53 to 1.79) | 0%
Myocardial infarction | 11.93 | 0.56 (0.06 to 5.02) | 60%
Stroke | 1 | 1.51 (0.30 to 7.52)^*^ | NA
Target revascularization | 13.36 | 1.61 (1.03 to 2.54) | NA
MACE | 11.49 | 1.36 (0.98 to 1.89) | 0%

* Results based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 140 Impact of distal balloon embolic protection devices versus control on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 6 | 0.82 (0.45 to 1.51) | 2.5%
Myocardial infarction | 6 | 0.67 (0.29 to 1.57) | 0%
Stroke | 6 | 0.48 (0.10 to 2.22)^*^ | NA
Target revascularization | 6 | 0.93 (0.61 to 1.42) | 0%
MACE | 6 | 0.87 (0.64 to 1.19) | 0%

* Result based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 141 Impact of proximal balloon embolic protection devices versus control on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 6 | 0.51 (0.11 to 2.33)^*^ | NA
Myocardial infarction | 6 | 1.01 (0.24 to 4.33)^*^ | NA
Stroke | 6 | 0.20 (0 to 1.93)^*^ | NA
Target revascularization | 6 | 0.71 (0.29 to 1.75)^*^ | NA
MACE | 6 | 0.74 (0.36 to 1.54)^*^ | NA

* Results based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 142 Impact of embolic protection devices combined on final health outcomes using the maximal duration of followup in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 8.31 | 0.87 (0.57 to 1.31) | 0%
Myocardial infarction | 8.27 | 0.83 (0.45 to 1.55) | 0%
Stroke | 3.74 | 0.68 (0.22 to 2.11) | 0%
Target revascularization | 8.60 | 1.11 (0.80 to 1.52) | 10%
MACE | 8.15 | 1.03 (0.82 to 1.29) | 4%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 143 Impact of catheter aspiration devices versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 0.79 | 0.65 (0.39 to 1.10) | 0%
Myocardial infarction | 0.77 | 0.55 (0.24 to 1.25) | 0%
Stroke | 0.79 | 3.18 (0.73 to 13.88) | 0%
Target revascularization | 0.70 | 0.85 (0.53 to 1.38) | 0%
MACE | 0.79 | 0.80 (0.57 to 1.12) | 0%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 144 Impact of mechanical thrombectomy devices versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 1 | 1.25 (0.47 to 3.32) | 48.7%
Myocardial infarction | 1 | 0.63 (0.21 to 1.96) | 0%
Stroke | 1 | 1.89 (0.55 to 6.48) | 0%
Target revascularization | 1 | 1.62 (0.21 to 12.55) | 62%
MACE | 1 | 1.28 (0.37 to 4.38) | 80.4%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 145 Impact of distal filter embolic protection devices versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 1 | 1.02 (0.50 to 2.08) | 0%
Myocardial infarction | 1 | 0.73 (0.12 to 4.44) | 44.3%
Stroke | 1 | 1.51 (0.30 to 7.52)^*^ | NA
Target revascularization | 1 | 3.02 (0.61 to 14.84) | NA
MACE | 1 | 1.29 (0.77 to 2.15) | 0%

* Results based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 146 Impact of distal balloon embolic protection devices versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 1 | 0.64 (0.30 to 1.39) | 0%
Myocardial infarction | 1 | 0.85 (0.32 to 2.23) | 0%
Stroke | 1 | 0.11 (0 to 0.94)^*^ | NA
Target revascularization | 1 | 1.38 (0.55 to 3.50) | 0%
MACE | 1 | 0.74 (0.44 to 1.23) | 0%

* Results based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 147 Impact of proximal balloon embolic protection devices versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I2 for Relative Risk
Mortality | 1 | 1.01 (0.14 to 7.10)^*^ | NA
Myocardial infarction | 1 | 0.68 (0.11 to 3.99)^*^ | NA
Stroke | 1 | 0.34 (0.01 to 8.23)^*^ | NA
Target revascularization | 1 | 0.51 (0.13 to 1.99)^*^ | NA
MACE | 1 | 0.61 (0.23 to 1.63)^*^ | NA

* Results based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 148 Impact of embolic protection devices combined versus control on final health outcomes at ≤ 30 days in randomized controlled trials evaluating patients with ST-segment elevation myocardial infarction

Final Health Outcome | Weighted Mean Followup (months) | Relative Risk (95% CI) | I^2^ for Relative Risk
Mortality | 1 | 0.84 (0.50 to 1.39) | 0%
Myocardial infarction | 1 | 0.83 (0.41 to 1.69) | 0%
Stroke | 1 | 0.56 (0.11 to 2.84) | 22.1%
Target revascularization | 1 | 1.24 (0.62 to 2.48) | 0%
MACE | 1 | 0.92 (0.66 to 1.30) | 0%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events

Table 149 In-hospital mortality in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.81 (0.23 to 2.86) | 0%
Mechanical Thrombectomy | 1.00 (0.24 to 4.16)^*^ | NA
Distal Filter Embolic Protection Devices | ---^†^ | ---^†^
Distal Balloon Embolic Protection Devices | 0.69 (0.24 to 2.03)^*^ | NA
Proximal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Embolic Protection Devices Combined | 0.69 (0.24 to 2.03)^*^ | NA

* Result is based on a single trial;

† Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval; NA=not applicable

Table 150 30-day mortality in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.61 (0.35 to 1.07) | 0%
Mechanical Thrombectomy | 1.25 (0.47 to 3.32) | 48.7%
Distal Filter Embolic Protection Devices | 1.02 (0.50 to 2.08) | 0%
Distal Balloon Embolic Protection Devices | 0.64 (0.30 to 1.39) | 0%
Proximal Balloon Embolic Protection Device | 1.01 (0.18 to 5.69)^*^ | NA
Embolic Protection Devices Combined | 0.84 ( 0.50 to 1.39) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 151 180-day mortality in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.89 (0.31 to 2.51) | 2.8%
Mechanical Thrombectomy | 1.35 (0.53 to 3.44) | 58.4%
Distal Filter Embolic Protection Devices | 1.25 (0.38 to 4.16)^*^ | NA
Distal Balloon Embolic Protection Devices | 0.86 (0.48 to 1.57) | 0%
Proximal Balloon Embolic Protection Devices | 0.51 (0.11, 2.33) | NA
Embolic Protection Devices Combined | 0.87 (0.52 to 1.46) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 152 365-day mortality in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.62 (0.39 to 0.98) | NA
Mechanical Thrombectomy | 0.50 (0.21 to 1.17) | NA
Distal Filter Embolic Protection Devices | 0.87 (0.43 to 1.78)^†^ | NA
Distal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | 0.87 (0.43 to 1.78)^†^ | NA

* Risk could not be calculated because no trials evaluated this outcome

† based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 153 In-hospital myocardial infarction in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.32 (0.03 to 3.06) | NA
Mechanical Thrombectomy | 1.00 (0.11 to 9.41)^*^ | NA
Distal Filter Embolic Protection Devices | ---^†^ | ---^†^
Distal Balloon Embolic Protection Devices | 0.32 (0.00 to 3.71)^*^ | NA
Proximal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Embolic Protection Devices Combined | 0.32 (0.00 to 3.71)^*^ | NA

* Result is based on a single trial;

† Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval; NA=not applicable

Table 154 30-day myocardial infarction in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.60 (0.25 to 1.45) | 0%
Mechanical Thrombectomy | 0.63 (0.21 to 1.96) | 0%
Distal Filter Embolic Protection Devices | 0.73 (0.12 to 4.44) | 44.3%
Distal Balloon Embolic Protection Devices | 0.85 (0.32 to 2.23) | 0%
Proximal Balloon Embolic Protection Devices | 0.68 (0.14 to 3.34)^*^ | NA
Embolic Protection Devices Combined | 0.83 (0.41 to 1.69) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 155 180-day myocardial infarction in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.70 (0.24 to 1.99) | 0%
Mechanical Thrombectomy | 0.57 (0.17 to 1.92) | NA
Distal Filter Embolic Protection Devices | 0.09 (0 to 0.74)^*^ | NA
Distal Balloon Embolic Protection Devices | 0.67 (0.29 to 1.57) | 0%
Proximal Balloon Embolic Protection Device | 1.01 (0.24, 4.33) | NA
Embolic Protection Devices Combined | 0.65 (0.31 to 1.33) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 156 365-day myocardial infarction in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.51 (0.26 to 1.00) | NA
Mechanical Thrombectomy | 0.66 (0.13 to 3.29) | NA
Distal Filter Embolic Protection Devices | 2.35 (0.61 to 8.90)^†^ | NA
Distal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | 2.35 (0.61 to 8.90)^†^ | NA

* Risk could not be calculated because no trials evaluated this outcome

† Based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 157 In-hospital stroke in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | 4.94 (0.52 to infinity) | NA
Mechanical Thrombectomy Devices | ---^*^ | ---^*^
Distal Filter Embolic Protection Devices | ---^†^ | ---^†^
Distal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Proximal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Embolic Protection Devices Combined | ---^†^ | ---^†^

* Risk could not be calculated because one trial evaluated this outcome and no events occurred;

† Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval; NA=not applicable

Table 158 30-day stroke in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 2.77 (0.51 to 14.98) | 0%
Mechanical Thrombectomy | 1.89 (0.55 to 6.48) | 0%
Distal Filter Embolic Protection Devices | 1.51 (0.30 to 7.52)^*^ | NA
Distal Balloon Embolic Protection Devices | 0.11 (0 to 0.94)^*^ | NA
Proximal Balloon Embolic Protection Devices | 0.34 (0 to 3.87)^*^ | NA
Embolic Protection Devices Combined | 0.56 (0.11 to 2.84) | 22.1%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 159 180-day stroke in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | ---^*^ | ---^*^
Mechanical Thrombectomy Devices | 2.05 (0.27 to 15.78) | NA
Distal Filter Embolic Protection Devices | ---^†^ | ---^†^
Distal Balloon Embolic Protection Devices | 0.48 (0.10 to 2.22)^‡^ | NA
Proximal Balloon Embolic Protection Devices | 0.20 (0.00 to 1.93) | NA
Embolic Protection Devices Combined | 0.39 (0.09 to 1.71) | NA

* Risk could not be calculated because one trial evaluated this outcome and no events occurred;

‡ Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 160 365-day stroke in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | ---^*^ | ---^*^
Mechanical Thrombectomy Devices | 1.99 (0.26 to 15.14) | NA
Distal Filter Embolic Protection Devices | ---^*^ | ---^*^
Distal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | ---^*^ | ---^*^

* Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval; NA=not applicable

Table 161 In-hospital target revascularization in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | 1.35 (0.26 to 6.94) | 0%
Mechanical Thrombectomy Devices | ---^*^ | ---^*^
Distal Filter Embolic Protection Devices | ---^†^ | ---^†^
Distal Balloon Embolic Protection Devices | 0.32 (0.00 to 3.71)^‡^ | NA
Proximal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Embolic Protection Devices Combined | 0.32 (0.00 to 3.71)^‡^ | NA

* Risk could not be calculated because one trial evaluated this outcome and no events occurred;

† Risk could not be calculated because no trials evaluated this outcome;

‡ Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 162 30-day target revascularization in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | 0.82 (0.50 to 1.35) | 0%
Mechanical Thrombectomy Devices | 1.62 (0.21 to 12.55) | 62%
Distal Filter Embolic Protection Devices | 3.02 (0.70 to 13.01)^*^ | NA
Distal Balloon Embolic Protection Devices | 1.38 (0.55 to 3.50) | 0%
Proximal Balloon Embolic Protection Devices | 0.51 (0.14 to 1.81)^*^ | NA
Embolic Protection Devices Combined | 1.24 (0.62 to 2.48) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 163 180-day target revascularization in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | 0.62 (0.40 to 0.96) | 0%
Mechanical Thrombectomy Devices | 0.55 (0.33 to 0.92) | NA
Distal Filter Embolic Protection Devices | 1.00 (0.35 to 2.82)^*^ | NA
Distal Balloon Embolic Protection Devices | 0.93 (0.61 to 1.42) | 0%
Proximal Balloon Embolic Protection Devices | 0.71 (0.29 to 1.75) | NA
Embolic Protection Devices Combined | 0.90 (0.63 to 1.30) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 164 365-day target revascularization in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration Devices | 0.87 (0.63 to 1.19) | NA
Mechanical Thrombectomy Devices | 0.68 (0.41 to 1.13) | NA
Distal Filter Embolic Protection Devices | 1.78 (1.09 to 2.93)^†^ | NA
Distal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | 1.78 (1.09 to 2.93)^†^ | NA

* Risk could not be calculated because no trials evaluated this outcome

† Based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 165 In-hospital MACE in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.97 (0.36 to 2.58) | 0%
Mechanical Thrombectomy | ---^*^ | ---^*^
Distal Filter Embolic Protection Devices | ---^*^ | ---^*^
Distal Balloon Embolic Protection Devices | ---^†^ | ---^†^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | ---^†^ | ---^†^

* Risk could not be calculated because no trials evaluated this outcome;

† Risk could not be calculated because one trial evaluated this outcome and no events occurred

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 166 30-day MACE in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.79 (0.56 to 1.13) | 0%
Mechanical Thrombectomy | 1.28 (0.37 to 4.38) | 80.4%
Distal Filter Embolic Protection Devices | 1.29 (0.77 to 2.15) | 0%
Distal Balloon Embolic Protection Devices | 0.74 (0.44 to 1.23) | 0%
Proximal Balloon Embolic Protection Devices | 0.61 (0.23 to 1.57)^*^ | NA
Embolic Protection Devices Combined | 0.92 (0.66 to 1.30) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 167 180-day MACE in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.66 (0.47to 0.94) | 0%
Mechanical Thrombectomy | 0.71 (0.41 to 1.20) | NA
Distal Filter Embolic Protection Devices | 1.10 (0.68 to 1.78) | NA
Distal Balloon Embolic Protection Devices | 0.87 (0.64 to 1.19) | 0%
Proximal Balloon Embolic Protection Devices | 0.74 (0.36 to 1.54) | NA
Embolic Protection Devices Combined | 0.91 (0.71 to 1.16) | 0%

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 168 365-day MACE in randomized controlled trials in patients with ST-segment elevation myocardial infarction

Device Category | Relative Risk (95% CI) | I^2^ for Relative Risk
Catheter Aspiration | 0.61 (0.26 to 1.41) | NA
Mechanical Thrombectomy | 0.66 (0.44 to 0.97) | NA
Distal Filter Embolic Protection Devices | 1.48 (1.03 to 2.15)^†^ | NA
Distal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Proximal Balloon Embolic Protection Devices | ---^*^ | ---^*^
Embolic Protection Devices Combined | 1.48 (1.03 to 2.15)^†^ | NA

* Risk could not be calculated because no trials evaluated this outcome

† Based on a single trial

Abbreviations: CI=confidence interval; MACE=major adverse cardiac events; NA=not applicable

Table 169 Impact of cathter aspiration devices versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 1.75 (1.44 to 2.14) | 69.2%
TIMI-3 | 1.07 (1.04 to 1.11) | 0%
Distal embolization | 0.48 (0.34 to 0.66) | 33.7%
No reflow | 0.45 (0.27 to 0.75) | 22.3%
ST-segment resolution | 1.39 (1.21 to 1.61) | 60.4%

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; TIMI=thrombolysis in myocardial infarction

Table 170 Impact of mechanical thrombectomy devices versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 1.07 (0.80 to 1.43) | 76.5%
TIMI-3 | 0.98 (0.92 to 1.04) | 67.5%
Distal embolization | 0.44 (0.17 to 1.12) | 41.6%
No reflow | 0.50 (0.17 to 1.48) | 41.7%
ST-segment resolution | 1.16 (0.99 to 1.36) | 75.1%

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; TIMI=thrombolysis in myocardial infarction

Table 171 Impact of distal filter embolic protection devices versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 0.97 (0.81 to 1.15) | NA
TIMI-3 | 1.02 (0.90 to 1.15) | 70.2%
Distal embolization | 0.63 (0.22 to 1.82) | NA
No reflow | 1.00 (0.18 to 5.55)^*^ | NA
ST-segment resolution | 1.05 (0.96 to 1.14) | 0%

* Result is based on a single trial

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; NA=not applicable; TIMI=thrombolysis in myocardial infarction

Table 172 Impact of distal balloon embolic protection devices versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 1.39 (1.15 to 1.69) | 43.5%
TIMI-3 | 1.09 (1.01 to 1.17) | 59.7%
Distal embolization | 1.10 (0.67 to 1.81) | 5.8%
No reflow | 0.51 (0.19 to 1.33) | 0%
ST-segment resolution | 1.08 (0.91 to 1.29) | 41.2%

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; TIMI=thrombolysis in myocardial infarction

Table 173 Impact of proximal balloon embolic protection devices versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 0.98 (0.88 to 1.10)^*^ | NA
TIMI-3 | 1.06 (0.98 to 1.16)^*^ | NA
Distal embolization | 0.71 (0.38 to 1.33)^*^ | NA
No reflow | ---^†^ | ---^†^
ST-segment resolution | 1.11 (0.97 to 1.28)^*^ | NA

* Result is based on a single trial;

† Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; NA=not applicable; TIMI=thrombolysis in myocardial infarction

Table 174 Impact of embolic protection devices combined versus control on intermediate health outcomes in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Intermediate health outcomes | Relative Risk (95% CI) | I^2^ for Relative Risk
MBG-3 | 1.20 (1.02 to 1.40) | 68.2%
TIMI-3 | 1.06 (1.01 to 1.12) | 55.4%
Distal embolization | 0.91 (0.64 to 1.30) | 0.2%
No reflow | 0.58 (0.25 to 1.37) | 0%
ST-segment resolution | 1.06 (1.00 to 1.13) | 0%

Abbreviations: CI=confidence interval; MBG=myocardial blush grade; TIMI=thrombolysis in myocardial infarction

Table 175 Impact of catheter aspiration devices versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | 0.30 (0.12 to 0.75) | 0%
Perforation | ---^*^ | ---^*^
Side-branch occlusion | 1.19 (0.40 to 3.54) | NA

* Risk could not be calculated because one trial evaluated the outcome and no events occurred

Abbreviations: CI=confidence interval; NA=not applicable

Table 176 Impact of mechanical trhombectomy devices versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | 1.51 (0.57 to 4.01)^*^ | NA
Perforation | 1.04 (0.15 to 7.04) | NA
Side-branch occlusion | 1.00 (0.11 to 9.41)^*^ | NA

* Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 177 Impact of distal filter embolic protection devices versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | ---^*^ | ---^*^
Perforation | ---^*^ | ---^*^
Side-branch occlusion | 0.33 (0.00 to 3.80)^†^ | NA

* Risk could not be calculated because one trial evaluated this outcome and no events occurred;

† Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 178 Impact of distal balloon embolic protection devices versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | ---^*^ | ---^*^
Perforation | 5.11 (0.53 to infinity)^†^ | NA
Side-branch occlusion | 0.93 (0.61 to 1.42) | NA

* Risk could not be calculated because one trial evaluated this outcome and no events occurred;

† Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

Table 179 Impact of proximal balloon embolic protection devices versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | ---^*^ | ---^*^
Perforation | ---^*^ | ---^*^
Side-branch occlusion | ---^*^ | ---^*^

* Risk could not be calculated because no trials evaluated this outcome

Abbreviations: CI=confidence interval

Table 180 Impact of embolic protection devices combined versus control on adverse events in randomized controlled trials of good methodological quality in patients with ST-segment elevation myocardial infarction

Adverse event | Relative Risk (95% CI) | I^2^ for Relative Risk
Coronary dissection | ---^*^ | ---^*^
Perforation | 5.11 (0.53 to infinity)^†^ | NA
Side-branch occlusion | 0.91 (0.60 to 1.39) | 0%

* Risk could not be calculated because in the two trials that evaluated this outcome no events occurred;

† Result is based on a single trial

Abbreviations: CI=confidence interval; NA=not applicable

## References for Evidence Tables

Migliorini A, Stabile A, Rodriguez AE, et al. Comparison of AngioJet Rheolytic Thrombectomy Before Direct Infarct Artery Stenting With Direct Stenting Alone in Patients With Acute Myocardial Infarction The JETSTENT Trial. J Am Coll Cardiol. 2010. [Epub ahead of print]. [pmid: 20691553].
Liistro F, Grotti S, Angioli P, et al. Impact of thrombus aspiration on myocardial tissue reperfusion and left ventricular functional recovery and remodeling after primary angioplasty. Circ Cardiovasc Interv. 2009;2:376-83. [pmid: 20031746].
Lipiecki J, Monzy S, Durel N, et al. Effect of thrombus aspiration on infarct size and left ventricular function in high-risk patients with acute myocardial infarction treated by percutaneous coronary intervention. Results of a prospective controlled pilot study. Am Heart J. 2009;157:583.e1-583.e7. [pmid: 19249433].
Sardella G, Mancone M, Bucciarelli-Ducci C, et al. Thrombus aspiration during primary percutaneous coronary intervention improves myocardial reperfusion and reduces infarct size: the EXPIRA (thrombectomy with export catheter in infarct-related artery during primary percutaneous coronary intervention) prospective, randomized trial. J Am Coll Cardiol. 2009;53:309-15. [pmid: 19161878].
Chevalier B, Gilard M, Lang I, et al. Systematic primary aspiration in acute myocardial percutaneous intervention: a multicentre randomised controlled trial of the export aspiration catheter. EuroIntervention. 2008;4:222-8. [pmid: 19110787].
Ikari Y, Sakurada M, Kozuma K, et al. Upfront thrombus aspiration in primary coronary intervention for patients with ST-segment elevation acute myocardial infarction: report of the VAMPIRE (VAcuuM asPIration thrombus REmoval) trial. JACC Cardiovasc Interv. 2008;1:424-31. [pmid: 19463340].
Tahk SJ, Choi BJ, Choi SY, et al. Distal protection device protects microvascular integrity during primary percutaneous intervention in acute myocardial infarction: a prospective, randomized, multicenter trial. Int J Cardiol. 2008;123:162-8. [pmid: 17490759].
Haeck JD, Koch KT, Bilodeau L, et al. Randomized comparison of primary percutaneous coronary intervention with combined proximal embolic protection and thrombus aspiration versus primary percutaneous coronary intervention alone in ST-segment elevation myocardial infarction: the PREPARE (PRoximal Embolic Protection in Acute myocardial infarction and Resolution of ST-Elevation) study. JACC Cardiovasc Interv. 2009;2:934-43. [pmid: 19850252].
Dudek D. Polish-Italian-Hungarian randomized thrombectomy trial [slide presentation]. Apr 23, 2010.
Moura R, Barreto F, Costa M, et al. Improvement of Reperfusion Rates With Thrombectomy Catheter in Acute Myocardial Infarction. J Am Coll Cardiol. 2009;53:A329.
Ciszewski M, Pregowski J, Teresinska A, et al. Aspiration Coronary Thrombectomy for Acute Myocardial Infarction Improves Myocardial Salvage Index. Single Center Randomized Study. Circulation. 2008;118:S764.
Antoniucci D, Valenti R, Migliorini A, et al. Comparison of rheolytic thrombectomy before direct infarct artery stenting versus direct stenting alone in patients undergoing percutaneous coronary intervention for acute myocardial infarction. Am J Cardiol. 2004;93:1033-5. [pmid: 15081450].
Parodi G, Valenti R, Migliorini A, et al. A randomized trial comparing rheolytic thrombectomy before infarct artery stenting with stenting alone in patients undergoing percutaneous coronary intervention for acute myocardial infarction. J Am Coll Cardiol. 2004;43:286A.
Lefevre T, Garcia E, Reimers B, et al. X-sizer for thrombectomy in acute myocardial infarction improves ST-segment resolution: results of the X-sizer in AMI for negligible embolization and optimal ST resolution (X AMINE ST) trial. J Am Coll Cardiol. 2005;46:246-52. [pmid: 16022950].
Lelfevre T, Ludwig J, Garcia E, et al. Randomized study to evaluate the effect on ST-segment resolution using the X-Sizer XT catheter system in acute myocardial infarction patients (X-AMINE ST study). Am J Cardiol. 2004;94:154E-5E.
Lefevre T, Ludwig J, Garcia E. X-SIZER in acute myocardial infarction. Results of a European Randomized Trial (XAMINE ST). Am J Cardiol. 2003;92:36L.
Lefevre T. Preliminary results of a randomized trial using X-SIZER in acute myocardial infarction for negligible embolization and optimal ST-segment resolution (XAMINE ST). Am J Cardiol. 2002;90:TCT266.
Lefevre T, Ludwig J, Nonnekens R, et al. Preliminary results of a randomized trial using X-SIZER in acute myocardial infarction for negligible embolization and optimal ST segment resolution (Xamine ST). Circulation. 2002;106:1663.
Garcia E. X-SIZER in AMI patients for negligible embolization and optimal ST resolution [slide presentation]. Apr 23, 2010.
Morice MC. Insights from completed studies-potential of futility? X-AMINE ST (thrombectomy): reperfusion and clinical results [slide presentation]. Apr 23, 2010.
Morice MC. Filters in AMI may work where balloon occlusion/aspiration systems don't: DIPLOMAT [slide presentation]. Apr 23, 2010.
Morice MC. Thrombectomy in AMI revisited: X AMINE ST update, and a trial of simple aspiration [slide presentation]. Apr 23, 2010.
Lefevre T, Ludwig J. X-Sizer in AMI patients for negligible embolization and optimal ST resolution [slide presentation]. Apr 23, 2010.
Lefevre T, Ludwig J. Results of trial data: X-Sizer in acute myocardial infarction to examine negligible embolization and ST-segment elevation resolution [slide presentation]. Apr 23, 2010.
Ali A, Cox D, Dib N, et al. Rheolytic thrombectomy with percutaneous coronary intervention for infarct size reduction in acute myocardial infarction: 30-day results from a multicenter randomized study. J Am Coll Cardiol. 2006;48:244-52. [pmid: 16843170].
Ali A. Angio-Jet rheolytic thrombectomy in patients undergoing primary angioplasty for acute myocardial infarction [slide presentation]. Apr 23, 2010.
Ali A. Is thrombectomy of benefit in any patients with STEMI? Long term and subset data from AiMI [slide presentation]. Apr 23, 2010.
Sianos G. Rheolytic thrombectomy after the failed AiMI trial: role in large thrombus burden and stent thrombosis [slide presentation]. Apr 23, 2010.
Napodano M, Pasquetto G, Sacca S, et al. Intracoronary thrombectomy improves myocardial reperfusion in patients undergoing direct angioplasty for acute myocardial infarction. J Am Coll Cardiol. 2003;42:1395-402. [pmid: 14563581].
Reimers B, Favero L, Napodano M. Defending the microcirculation: distal protection and thrombectomy devices in the coronary circulation [slide presentation]. Apr 23, 2010.
Antoniucci D, on behalf of the JETSTENT Investigators. Comparison of Angiojet rheolytic thrombectomy before direct infarct related artery stenting in patients with acute myocardial infarction : the JETSTENT trial [slide presentation]. Apr 23, 2010.
Antoniucci D, on behalf of the JETSTENT Investigators. Comparison of Angiojet rheolytic thrombectomy before direct infarct related artery stenting in patients with acute myocardial infarction : the JETSTENT trial [slide presentation]. Apr 23, 2010.
Liistro F. Impact of thrombus aspiration on myocardial tissue reperfusion and left ventricular functional recovery and remodeling after primary angioplasty [slide presentation]. Apr 23, 2010.
Sardella G, Mancone M, Canali E, et al. Impact of thrombectomy with Export catheter in infarct related artery during primary PCI on procedural outcome in patients with acute myocardial infarction (EXPIRA trial). 24 month clinical outcomes [slide presentation]. Apr 23, 2010.
Sardella G, Mancone M, Di Roma A, et al. Impact of thrombectomy with Export catheter in infarct related artery during primary PCI on procedural outcomes in patients with acute myocardial infarction (EXPIRA trial) [slide presentation]. Apr 23, 2010.
Chevalier B, Parikh K, Boschat J, et al. EXPORT Study first report [slide presentation]. Apr 23, 2010.
Ciszewski M, Pregowski J, Teresinska A, et al. Randomized study on coronary thrombectomy for acute myocardial infarction with ST segment elevation. Eur Heart J. 2006;27(suppl):771.
Ciszewski M, Pregowski J, Debski A, et al. Randomized study on coronary thrombectomy for acute myocardial infarction with ST segment elevation. Am J Cardiol. 2006;98:60M-1M. [pmid: 16784921].
Kozuma K, Ikari Y, Fujii K, et al. Three-year Clinical Follow-up of the Vampire Study in St Elevation Acute Myocardial Infarction (STEMI) Patients With Thrombus Aspiration Prior to Coronary Intervention. Circulation. 2009;120:S985.
Kozuma K, Ikari Y, Sakurada M, et al. Long-term clinical follow-up in ST elevation acute myocardial infarction (STEMI) patients with thrombus aspiration prior to coronary intervention, 2-year results of the Vampire study. Circulation. 2007;116:1784. [pmid: 17909107].
Kozuma K, Suzuki N, Tanabe K, et al. The impact of the thrombus aspiration on the final TIMI flow in patients with ST-elevation myocardial infarction (STEMI). J Am Coll Cardiol. 2006;47:185A-6A.
Ikari Y, Kawano S, Sakurada M, et al. Thrombus aspiration prior to coronary intervention improves myocardial microcirculation in patients with ST elevation acute myocardial infarction, the VAMPIRE study. Circulation. 2005;112:3091.
Isshiki T, Ikari Y, Sakurada M, et al. Thrombus aspiration prior to coronary intervention improves myocardial microcirculation in patients with ST elevation acute myocardial infarction, the VAMPIRE study. Am J Cardiol. 2006;98:60M. [pmid: 16784921].
Isshiki T, Kozuma K, Sakurada M, et al. Eur Heart J. 2006;27:1022.
Kyono H, Kozuma K, Ikari Y, et al. Thrombectomy Improves Angiographic Outcome in ST-Segment Elevation Myocardial Infarction Cases without Visible Thrombus: Subanalysis from the VAMPIRE trial. J Am Coll Cardiol. 2009;53:A64.
Isshiki T. VAMPIRE: Vacuum aspiration thrombus removal [slide presentation]. Apr 23, 2010.
Svilaas T, Vlaar PJ, van der Horst IC, et al. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med. 2008;358:557-67. [pmid: 18256391].
Fokkema ML, van der Vleuten PA, Vlaar PJ, et al. Incidence, predictors, and outcome of reinfarction and stent thrombosis within one year after primary percutaneous coronary intervention for ST-elevation myocardial infarction. Catheter Cardiovasc Interv. 2009;73:627-34. [pmid: 19309712].
Vlaar PJ, Svilaas T, van der Horst IC, et al. Cardiac death and reinfarction after 1 year in the Thrombus Aspiration during Percutaneous coronary intervention in Acute myocardial infarction Study (TAPAS): a 1-year follow-up study. Lancet. 2008;371:1915-20. [pmid: 18539223].
Svilaas T, van der Horst IC, Zijlstra F. Thrombus Aspiration during Percutaneous coronary intervention in Acute myocardial infarction Study (TAPAS)--study design. Am Heart J. 2006;151:597.e1-597.e7. [pmid: 16504620].
van der Vleuten PA, Vogelzang M, Svilaas T, et al. Predictive value of Q waves on the 12-lead electrocardiogram after reperfusion therapy for ST elevation myocardial infarction. J Electrocardiol. 2009;42:310-8. [pmid: 19362318].
de Smet BJ. Thrombus aspiration during percutaneous coronary intervention in acute myocardial infarction study (TAPAS): mortality and MACE at 1 year followup [slide presentation]. Apr 23, 2010.
Chao CL, Hung CS, Lin YH, et al. Time-dependent benefit of initial thrombosuction on myocardial reperfusion in primary percutaneous coronary intervention. Int J Clin Pract. 2008;62:555-61. [pmid: 18067561].
De Luca L, Sardella G, Davidson CJ, et al. Impact of intracoronary aspiration thrombectomy during primary angioplasty on left ventricular remodelling in patients with anterior ST elevation myocardial infarction. Heart. 2006;92:951-7. [pmid: 16251226].
De Luca L, Sardella G, Di Roma A, et al. Effects of thrombectomy on long-term mortality after primary percutaneous coronary intervention. Am J Cardiol. 2004;94:155E.
Kaltoft A, Bottcher M, Nielsen SS, et al. Routine thrombectomy in percutaneous coronary intervention for acute ST-segment-elevation myocardial infarction: a randomized, controlled trial. Circulation. 2006;114:40-7. [pmid: 16801464].
Andersen NH, Karlsen FM, Gerdes JC, et al. No beneficial effects of coronary thrombectomy on left ventricular systolic and diastolic function in patients with acute S-T elevation myocardial infarction: a randomized clinical trial. J Am Soc Echocardiogr. 2007;20:724-30. [pmid: 17543743].
Kaltoft A, Bottcher M, Nielsen SS, et al. Thrombectomy as an adjunct to percutaneous coronry intervention in ST-segment elevation myocardial infarction [slide presentation]. Apr 23, 2010.
Silva-Orrego P, Colombo P, Bigi R, et al. Thrombus aspiration before primary angioplasty improves myocardial reperfusion in acute myocardial infarction: the DEAR-MI (Dethrombosis to Enhance Acute Reperfusion in Myocardial Infarction) study. J Am Coll Cardiol. 2006;48:1552-9. [pmid: 17045887].
Silva-Orrego P, Bigi R, Colombo P, et al. Direct stenting after thrombus removal before primary angioplasty in acute myocardial infarction. J Intervent Cardiol. 2008;21:300-6. [pmid: 18754965].
Colombo P, Silva B, Bigi R, et al. Thrombus aspiration improves coronary flow and myocardial reperfusion in acute myocardial infarction: Final results of the DEAR MI (dethrombosis to enhance acute reperfusion in myocardial infarction) study. Am J Cardiol. 2005;96:74H-5H. [pmid: 15979438].
Colombo P, Silva P, Delgado A, et al. Thrombus aspiration with the pronto extraction catheter before standard percutaneous coronary intervention improves myocardial reperfusion: Preliminary results of a prospective randomized study. Am J Cardiol. 2004;94:12E-3E.
Colombo P, Orrego PSOS, Bigi RB, et al. Thrombus aspiration improves myocardial reperfusion in acute myocardial infarction: the DEAR-MI (Dethrombosis to Enhance Acute Reperfusion in Myocardial Infarction) study. Eur Heart J. 2006;27:771-2.
Oreglia JA, Silva-Orrego P, Colombo P, et al. Impact of thrombus aspiration in acute myocardial infarction on procedural aspects of primary percutancous intervention. Am J Cardiol. 2006;98:25M.
SilvaOrrego P, Colombo P, Delgado A, et al. DEAR-MI: A randomized study comparing standard primary PCI versus PCI with thrombus aspiration in acute myocardial infarction [slide presentation]. Apr 23, 2010.
Oreglia J, SilvaOrrego P, Colombo P, et al. Impact of thrombus aspiration in acute myocardial infarction on procedural aspects of primary percutaneous intervention [slide presentation]. Apr 23, 2010.
SilvaOrrego P. DEAR-MI: Dethrombosis to enhance acute reperfusion in myocardial infarction [slide presentation]. Apr 23, 2010.
Burzotta F, Trani C, Romagnoli E, et al. Manual thrombus-aspiration improves myocardial reperfusion: the randomized evaluation of the effect of mechanical reduction of distal embolization by thrombus-aspiration in primary and rescue angioplasty (REMEDIA) trial. J Am Coll Cardiol. 2005;46:371-6. [pmid: 16022970].
Galiuto L, Garramone B, Burzotta F, et al. Thrombus aspiration reduces microvascular obstruction after primary coronary intervention: a myocardial contrast echocardiography substudy of the REMEDIA Trial. J Am Coll Cardiol. 2006;48:1355-60. [pmid: 17010794].
Noel B, morice MC, Lefevre T. Thromboaspiration in acute ST elevation MI improves myocardial infarction. Circulation. 2005;112(Suppl. II):519.
Lee SY, Joon HD, June N, et al. Export aspiration catheter thrombo-suction before actual primary PCI in AMI: TSUNAMI study. Circulation. 2006;114:597. [pmid: 16894049].
Dudek D, Mielecki W, Chyrchel M, et al. Percutaneous thrombectomy before stenting in acute myocardial infarction-randomized study. Eur Heart J. 2004;25:421.
Dudek D, Mielecki W, Legutko J, et al. Percutaneous thrombectomy with the RESCUE system in acute myocardial infarction. Kardiol Pol. 2004;61:523-33. [pmid: 15815753].
Kelbaek H, Terkelsen CJ, Helqvist S, et al. Randomized comparison of distal protection versus conventional treatment in primary percutaneous coronary intervention: the drug elution and distal protection in ST-elevation myocardial infarction (DEDICATION) trial. J Am Coll Cardiol. 2008;51:899-905. [pmid: 18308157].
Kaltoft A, Nielsen SS, Terkelsen CJ, et al. Scintigraphic evaluation of routine filterwire distal protection in percutaneous coronary intervention for acute ST-segment elevation myocardial infarction: a randomized controlled trial. J Nucl Cardiol. 2009;16:784-91. [pmid: 19521742].
Kofoed KF, Kelbaek H, Thuesen L, et al. Clinical Outcome and Left Ventricular Contractile Function After Distal Protection In Primary Percutaneous Coronary Intervention The Drug Elution and Distal Protection in ST-Elevation Myocardial Infarction (DEDICATION) Trial. Circulation. 2008;118:S763.
Thuesen L, Kelbaek H, Lassen JF, et al. Randomized comparison of the effect of distal protection and drug eluting stent versus bare metal stent implantation during percutaneous coronary intervention for TS-segment elevation myocardial infarction [slide presentation]. Apr 23, 2010.
Cura F, Escudero AG, Grinfeld L, et al. J Am Coll Cardiol. 2006;47:186A.
Cura F, Garcia E, Trivi M, et al. Protection of distal embolization in high-risk patients with acute ST-segment elevation myocardial infarction randomized controlled trial 6 month results [slide presentation]. Apr 23, 2010.
Cura FA, Escudero AG, Berrocal D, et al. Protection of Distal Embolization in High-Risk Patients with Acute ST-Segment Elevation Myocardial Infarction (PREMIAR). Am J Cardiol. 2007;99:357-63. [pmid: 17261398].
Cura FA, Padilla LT, Damonte A, et al. Protection of distal embolization in high-risk patients with acute ST-segment elevation myocardial infarction (PREMIAR) randomized controlled trial: 6-month results. Am J Cardiol. 2006;98:38M-9M.
Guetta V. The UPFLOW MI trial [slide presentation]. Apr 23, 2010.
Guetta V, Mosseri M, Shechter M, et al. Safety and efficacy of the FilterWire EZ in acute ST-segment elevation myocardial infarction. Am J Cardiol. 2007;99:911-5. [pmid: 17398182].
Lefevre T, Guyon P, Reimers B, et al. Distal protection in acute myocardial infarction: final results of the randomized DIPLOMAT study. Eur Heart J. 2004;25:420.
Lefevre T, Guyon P, Reimers B, et al. Evaluation of a distal protection filter device in patients with acute myocardial infarction: The DIPLOMAT study. Am J Cardiol. 2003;92:37L-8L.
Lefevre T, Guyon P, Reimers B, et al. Evaluation of a distal protection filter device in patients with acute myocardial infarction: Final results of the DIPLOMAT study. J Am Coll Cardiol. 2004;43:72A.
Tahk SJ, Chae IH, Choi SY, et al. Fate of unprotected side branches due to distal embolization during stent implantation for acute coronary syndromes using distal protection procedure. Circulation. 2004;110:3510.
Hahn JY, Gwon HC, Choe YH, et al. Effects of balloon-based distal protection during primary percutaneous coronary intervention on early and late infarct size and left ventricular remodeling: a pilot study using serial contrast-enhanced magnetic resonance imaging. Am Heart J. 2007;153:665.e1-665.e8. [pmid: 17383309].
Hahn JY, Gwon HC, Choe YH, et al. Effects of balloon-based distal protection during primary percutaneous coronary intervention on early and late infarct size and left ventricular remodeling: Serial contrast-enhanced magnetic resonance imaging analysis. Am J Cardiol. 2007;99:42F. [pmid: 17196459].
Rhee I, Gwon HC, Choe YH, et al. Distal protection reduces infaret size after primary angioplasty in acute myocardial infarction: Magnetic resonance imaging study. Am J Cardiol. 2005;95:10A.
Rhee I, Gwon HC, Choi YH, et al. Distal protection reduces infarct size after primary angioplasty in acute myocardial infarction: Magnetic resonance imaging. Am J Cardiol. 2004;94:36E.
Matsuo A, Inoue N, Suzuki K, et al. Limitations of using a GuardWire temporary occlusion and aspiration system in patients with acute myocardial infarction: multicenter investigation of coronary artery protection with a distal occlusion device in acute myocardial infarction (MICADO). J Invasive Cardiol. 2007;19:132-8. [pmid: 17341781].
Fujita N, Suwa S, Koyama S, et al. The efficacy of distal embolic protection device during an acute myocardial infarction: Early and long-term results. Am J Cardiol. 2004;94:34E.
Ito Y, Muramatsu T, Fuijita N, et al. Effectiveness of the PercuSurge distal embolic protection device in treatment of high-risk cases of acute myocardial infarction by intravenous ultrasound analyses: Data from the Japanese ASPARAGUS trial. Am J Cardiol. 2005;95:1A. [pmid: 15619385].
Muramatsu T. The Japanese ASPARGUS trial [slide presentation]. Apr 23, 2010.
Zhou BQ, Tahk SJ. Effect of a distal protection device on epicardial blood flow and myocardial perfusion in primary percutaneous coronary intervention. J Zhejiang Univ Sci B. 2007;8:575-9. [pmid: 17657860].
Stone GW, Webb J, Cox DA, et al. Distal microcirculatory protection during percutaneous coronary intervention in acute ST-segment elevation myocardial infarction: a randomized controlled trial. JAMA. 2005;293:1063-72. [pmid: 15741528].
Marso SP, Miller T, Rutherford BD, et al. Comparison of myocardial reperfusion in patients undergoing percutaneous coronary intervention in ST-segment elevation acute myocardial infarction with versus without diabetes mellitus (from the EMERALD Trial). Am J Cardiol. 2007;100:206-10. [pmid: 17631071].
Brodie BR, Webb J, Cox DA, et al. Impact of time to treatment on myocardial reperfusion and infarct size with primary percutaneous coronary intervention for acute myocardial infarction (from the EMERALD Trial). Am J Cardiol. 2007;99:1680-6. [pmid: 17560875].
Dangas G, Stone GW, Weinberg MD, et al. Contemporary outcomes of rescue percutaneous coronary intervention for acute myocardial infarction: comparison with primary angioplasty and the role of distal protection devices (EMERALD trial). Am Heart J. 2008;155:1090-6. [pmid: 18513524].
Stone GW, Webb J, Cox DA, et al. Primary angioplasty in acute myocardial infarction with distal protection of the microcirculation: Principal results from the prospective, randomized EMERALD trial. J Am Coll Cardiol. 2004;43:285A-6A.
Stone GW, Cox DA, Brodie BR, et al. Primary angioplasty in acute myocardial infarction with distal protection of the microcirculation: Results from the roll-in phase of the EMERALD trial. Circulation. 2003;108:1913.
Stone GW. The EMERALD trial Guardwire distal protection in AMI 6 month results and analysis [slide presentation]. Apr 23, 2010.
Okamura A, Ito H, Iwakura K, et al. Detection of embolic particles with the Doppler guide wire during coronary intervention in patients with acute myocardial infarction: efficacy of distal protection device. J Am Coll Cardiol. 2005;45:212-5. [pmid: 15653017].
Haeck JD, Koch KT, Bilodeau L, et al. Randomized Comparison of Primary Percutaneous Coronary Intervention With Combined Proximal Embolic Protection and Thrombus Aspiration and Primary Percutaneous Coronary Intervention Alone in ST-segment Elevation Myocardial Infarction. J Am Coll Cardiol. 2009;53:A28.
Koch KT, Haeck JD, Tijssen JG, et al. A prospective randomized trial of proximal microcirculatory protection in patients with acute myocardial infarction undergoing primary PCI [slide presentation]. Apr 23, 2010.
Koch K, Haeck J, Bilodeau L, et al. Randomized Comparison of Primary Percutaneous Coronary Intervention with Combined Proximal Embolic Protection and Thrombus Aspiration versus Primary Percutaneous Coronary Intervention Alone in ST-segment Elevation Myocardial Infarction. Am J Cardiol. 2009;103:AS46.
Parikh KH, Shah HA, Chag MC, et al. Efficacy of PercuSurge in acute myocardial infarction patients undergoing revascularization with a special emphasis on procedural time. Indian Heart J. 2008;60:101-19. [pmid: 19218717].
Parikh KH, Shah HA, Shah JN, et al. Study of percusurge in acute myocardial infarction patients undergoing revascularization with special emphasis on procedural time. [abstract]. Indian Heart J. 2006;58. Abstract-119.
Parikh KH, Shah HD, Chag MC, et al. Revascularization in acute myocardial infarction using Percusurge in distal protection acronym: RAPID. World Heart Journal. 2008;1:35-47.
Gick M, Jander N, Bestehorn HP, et al. Randomized evaluation of the effects of filter-based distal protection on myocardial perfusion and infarct size after primary percutaneous catheter intervention in myocardial infarction with and without ST-segment elevation. Circulation. 2005;112:1462-9. [pmid: 16129793].
Sardella G, De Luca L, Mancone M, et al. Impact of thromboaspiration device during primary angioplasty on left ventricular remodeling in patients with acute anterior myocardial infarction. Circulation. 2005;112(Suppl. II):519.
Kunii H, Kijima M, Araki T, et al. Lack of efficacy of intracoronary thrombus aspiration before coronary stenting in patients with acute myocardial infarction: A multicenter randomized trial. J Am Coll Cardiol. 2004;43:245A-6A.
Kunii H, Kyoritsu I, Tamaki K, et al. Intracoronary thrombus aspiration before coronary stenting in patients with acute myocardial infarction: A multicenter randomized trial. Circulation. 2003;108:1911.
Nanasato M, Hirayama H, Muramatsu T, et al. Impact of angioplasty with distal protection device on myocardial reperfusion. J Am Coll Cardiol. 2004;43(Suppl. 1):246A.
Matsushita M, Muramatsu T, Tsukahara R, et al. Effectiveness of percutaneous coronary intervention using distal protection for acute myocardial infarction in reducing microvascular obstruction. Am J Cardiol. 2003;92:191L.
Matsushita M, Muramatsu T, Tsukahara R, et al. Effectiveness of PCI using distal protection for AMI in reducing microvascular obstruction. Circulation. 2003;108:2913.
Muramatsu T, Kozuma K, Tsukahara R, et al. Comparison of myocardial perfusion by distal protection before and after primary stenting for acute myocardial infarction: angiographic and clinical results of a randomized controlled trial. Catheter Cardiovasc Interv. 2007;70:677-82. [pmid: 17621653].
Gick M, Jander N, Bestehorn H, et al. Randomised study on the effectiveness of a filter device for distal protection during direct percutaneous catheter intervention for acute myocardial infarction. PROMISE Study-6 month follow-up. Eur Heart J. 2005;26:P2216.
Duan YY, Zhang HB, Liu LW, et al. Effects of distal protection on left ventricular function in acute anterior myocardial infarction: a Doppler echocardiographic study. Int J Cardiovasc Imaging. 2010;26:125-33. [pmid: 19802729].
Pan W, Liu HW, Wang LF, et al. Effect of percutaneous thrombectomy on echocardiographic measures of myocardial microcirculation in elderly patients with acute myocardial infarction. Coron Artery Dis. 2010;21:121-5. [pmid: 20134319].
Ito N, Nanto S, Doi Y, et al. Distal protection during primary coronary intervention can preserve the index of microcirculatory resistance in patients with acute anterior ST-segment elevation myocardial infarction. Circ J. 2010;75:94-8. [pmid: 21116072].
Dudek D, Mielecki W, Burzotta F, et al. Thrombus aspiration followed by direct stenting: a novel strategy of primary percutaneous coronary intervention in ST-segment elevation myocardial infarction. Results of the Polish-Italian-Hungarian RAndomized ThrombEctomy Trial (PIHRATE Trial). Am Heart J. 2010;160:966-72. [pmid: 21095287].
Sardella G, Mancone M, Canali E, et al. Impact of thrombectomy with EXPort Catheter in Infarct-Related Artery during Primary Percutaneous Coronary Intervention (EXPIRA Trial) on cardiac death. Am J Cardiol. 2010;106:624-9. [pmid: 20723635].
Kaltoft A, Kelbaek H, Klovgaard L, et al. Increased rate of stent thrombosis and target lesion revascularization after filter protection in primary percutaneous coronary intervention for ST-segment elevation myocardial infarction: 15-month follow-up of the DEDICATION (Drug Elution and Distal Protection in ST Elevation Myocardial Infarction) trial. J Am Coll Cardiol. 2010;55:867-71. [pmid: 20185036].
Haeck JD, Kuijt WJ, Koch KT, et al. Infarct size and left ventricular function in the PRoximal Embolic Protection in Acute myocardial infarction and Resolution of ST-segment Elevation (PREPARE) trial: ancillary cardiovascular magnetic resonance study. Heart. 2010;96:190-5. [pmid: 19858136].
Kim JH, Sim DS, Cho MC, et al. Clinical benefits of thrombus aspiration during primary percutaneous coronary intervention for acute ST-Elevation Myocardial Infarction. Am J Cardio. 2010;105:31B.
De Vita M, Burzotta F, Porto I, et al. Thrombus aspiration in ST elevation myocardial infarction: comparative efficacy in patients treated early and late after onset of symptoms. Heart. 2010;96:1287-90. [pmid: 20659947].
Beaudoin J, Dery JP, Lachance P, et al. Impact of thrombus aspiration on angiographic and clinical outcomes in patients with ST-elevation myocardial infarction. Cardiovasc Revasc Med. 2010;11:218-22. [pmid: 20934652].
Chinnaiyan KM, Grines CL, O'Neill WW, et al. Safety of AngioJet thrombectomy in acute ST-segment elevation myocardial infarction: a large, single-center experience. J Invasive Cardiol. 2006;18:1721-21C. [pmid: 16883027].
Cohen R, Domniez T, Foucher R, et al. Intracoronary thrombectomy with the export aspiration catheter before angioplasty in patients with ST-segment elevation myocardial infarction. J Interv Cardiol. 2007;20:136-42. [pmid: 17391222].
Ko J, Jeong MH, Ahn YK, et al. Distal Protection Device in Primary Percutaneous Coronary Intervention for Fresh Acute Myocardial Infarction: Data From Kamir (Korean Acute Myocardial Infarction Registry). Circulation. 2009;120:S925-6.
Mehran R, Brodie B, Cox DA, et al. The Harmonizing Outcomes with RevasculariZatiON and Stents in Acute Myocardial Infarction (HORIZONS-AMI) Trial: study design and rationale. Am Heart J. 2008;156:44-56. [pmid: 18585496].
Nakatani D, Sato H, Sakata Y, et al. Effect of intracoronary thrombectomy on 30-day mortality in patients with acute myocardial infarction. Am J Cardiol. 2007;100:1212-7. [pmid: 17920359].
Nakatani D, Sato H, Sakata Y, et al. Clinical impact of intracoronary thrombectomy on 30-day mortality in patients with acute myocardial infarction who underwent percutaneous coronary intervention. Circulation. 2006;114:740.
Nilsen DW, Wu R, Lansky AJ, et al. Impact of Thrombus Aspiration in Patients With STEMI Undergoing Primary PCI: Analysis From the HORIZONS-AMI Trial. Circulation. 2009;120:S986.
Nilsen DWT, Wu R, Nordrehaug JE, et al. Impact of Thrombus Aspiration during Primary Percutaneous Coronary Intervention in Acute Myocardial Infarction: Analysis from the HORIZONS-AMI Trial. Am J Cardiol. 2009;104:3D-4D.
Simonton CA 3rd, Brodie BR, Wilson H, et al. AngioJet experience from the multi-center STENT Registry. J Invasive Cardiol. 2006;18:22-3. [pmid: 16883028].
Kramer MC, van der Wal AC, Koch KT, et al. Presence of older thrombus is an independent predictor of long-term mortality in patients with ST-elevation myocardial infarction treated with thrombus aspiration during primary percutaneous coronary intervention. Circulation. 2008;118:1810-6. [pmid: 18852369].
Webster MW. Vascular protection in high risk non-ST-segment elevation acute coronary syndromes [slide presentation]. Apr 23, 2010.
Dudek D, Bartus S, Zmudka K, et al. Safety and efficacy of ANGIOGUARD protection device for the prevention of distal embolization during PCI in patients with unstable angina. Przegl Lek. 2003;60:499-503. [pmid: 14974339].
Bartus S, Dudek D, Legutko J, et al. Safety and efficacy of Angioguard protection device for prevention of distal embolization during percutaneous coronary intervention in patients with unstable angina. Eur Heart J. 2002;23:552.
Sardella G, Mancone M, Nguyen BL, et al. The effect of thrombectomy on myocardial blush in primary angioplasty: the Randomized Evaluation of Thrombus Aspiration by two thrombectomy devices in acute Myocardial Infarction (RETAMI) trial. Catheter Cardiovasc Interv. 2008;71:84-91. [pmid: 17985382].
Sardella G, Mancone M, Colantonio R, et al. Randomized evaluation of the effect of thrombus aspiration by two different thrombectomy devices on myocardial blush during primary PCI. J Am Coll Cardiol. 2007;49:30B.
Yan HB, Wang J, Li N, et al. Diver CE versus Guardwire Plus for thrombectomy in patients with inferior myocardial infarction: a trial of aspiration of thrombus during primary angioplasty for inferior myocardial infarction. Chin Med J. 2007;120:557-61. [pmid: 17442202].
Li N, Yan HB, Zhu XL, et al. Diver CE versus Guardwire Plus for thrombectomy during primary angioplasty for inferior myocardial infarction. Chung Hua Hsin Hsueh Kuan Ping Tsa Chih. 2007;35:461-5. [pmid: 17711691].
Wita K, Lelek M, Filipecki A, et al. Microvascular damage prevention with thrombaspiration during primary percutaneous intervention in acute myocardial infarction. Coron Artery Dis. 2009;20:51-7. [pmid: 18997622].
Ozaki Y, Nomura M, Nakayama T, et al. Effects of thrombus suction therapy on myocardial blood flow disorders in males with acute inferior myocardial infarction. J Med Invest. 2006;53:167-73. [pmid: 16538011].
Ochala A, Smolka G, Wojakowski W, et al. Prospective randomised study to evaluate effectiveness of distal embolic protection compared to abciximab administration in reduction of microembolic complications of primary coronary angioplasty. Kardiol Pol. 2007;65:672-80. [pmid: 17629829].
Yamamoto S, Kamihata H, Sutani Y, et al. Effects of intravenous administration of tissue plasminogen activator before thrombectomy in patients with acute myocardial infarction. Circ J. 2006;70:243-7. [pmid: 16501287].
Beran G, Lang I, Schreiber W, et al. Intracoronary thrombectomy with the X-sizer catheter system improves epicardial flow and accelerates ST-segment resolution in patients with acute coronary syndrome: a prospective, randomized, controlled study. Circulation. 2002;105:2355-60. [pmid: 12021220].
Beran G, Lang I, Syeda B, et al. Intracoronary thrombectomy in acute coronary syndrome with a new percutaneous device: The Vienna X-Sizer study. Am J Cardiol. 2001;88:TCT189.
Kanaya T, Oida A, Sugimura H, et al. A distal protection method combined with thrombectomy and stenting prevents slow flow phenomenon following coronary artery intervention for patients with acute myocardial infarction. Circulation. 2003;107:P22.
Tamhane UU, Chetcuti S, Hameed I, et al. Safety and efficacy of thrombectomy in patients undergoing primary percutaneous coronary intervention for acute ST elevation MI: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord. 2010;10:10. [pmid: 20187958].
Inaba Y, Chen JA, Mehta N, et al. Impact of single or multicentre study design on the results of trials examining the efficacy of adjunctive devices to prevent distal embolisation during acute myocardial infarction. EuroIntervention. 2009;5:375-83. [pmid: 19736164].
Burzotta F, De Vita M, Gu YL, et al. Clinical impact of thrombectomy in acute ST-elevation myocardial infarction: an individual patient-data pooled analysis of 11 trials. Eur Heart J. 2009;30:2193-203. [pmid: 19726437].
De Vita M, Burzotta F, Biondi-Zoccai GG, et al. Individual patient-data meta-analysis comparing clinical outcome in patients with ST-elevation myocardial infarction treated with percutaneous coronary intervention with or without prior thrombectomy. ATTEMPT study: a pooled Analysis of Trials on ThrombEctomy in acute Myocardial infarction based on individual PatienT data. Vasc Health Risk Manag. 2009;5:243-7. [pmid: 19436647].
Amin AP, Mamtani MR, Kulkarni H. Factors influencing the benefit of adjunctive devices during percutaneous coronary intervention in ST-segment elevation myocardial infarction: meta-analysis and meta-regression. J Intervent Cardiol. 2009;22:49-60. [pmid: 19141090].
Bavry AA, Kumbhani DJ, Bhatt DL. Role of adjunctive thrombectomy and embolic protection devices in acute myocardial infarction: a comprehensive meta-analysis of randomized trials. Eur Heart J. 2008;29:2989-3001. [pmid: 18812323].
Burzotta F, Testa L, Giannico F, et al. Adjunctive devices in primary or rescue PCI: a meta-analysis of randomized trials. Int J Cardiol. 2008;123:313-21. [pmid: 17383756].
De Luca G, Dudek D, Sardella G, et al. Adjunctive manual thrombectomy improves myocardial perfusion and mortality in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction: a meta-analysis of randomized trials. Eur Heart J. 2008;29:3002-10. [pmid: 18775918].
Grines CL, Nelson TR, Safian RD, et al. A Bayesian meta-analysis comparing AngioJet thrombectomy to percutaneous coronary intervention alone in acute myocardial infarction. J Intervent Cardiol. 2008;21:459-82. [pmid: 19018943].
De Luca G, Suryapranata H, Stone GW, et al. Adjunctive mechanical devices to prevent distal embolization in patients undergoing mechanical revascularization for acute myocardial infarction: a meta-analysis of randomized trials. Am Heart J. 2007;153:343-53. [pmid: 17307410].
Kunadian B, Dunning J, Vijayalakshmi K, et al. Meta-analysis of randomized trials comparing anti-embolic devices with standard PCI for improving myocardial reperfusion in patients with acute myocardial infarction. Catheter Cardiovasc Interv. 2007;69:488-96. [pmid: 17286249].
Masotti M, Salazar H, Kiamco R, et al. Is the routine use of thrombectomy and distal protection devices of clinical benefit in acute myocardial infarction? A meta-analysis. Am J Cardiol. 2007;99:5F. [pmid: 17196453].
Mongeon F, Belisle P, Joseph L, et al. Primary percutaneous coronary intervention in acute myocardial infarction with or without thrombectomy: a meta-analysis. J Am Coll Cardiol. 2008;51:A243.
Brahmbhatt T, Marks DS, Cinquegrani M, et al. Improved angiographic and electrocardiographic, but not clinical outcomes, following coronary thrombectomy in patients with ST elevation myocardial infarction: a meta-analysis. Am J Cardiol. 2006;98:61M.
Salazar H, Masotti M, Ruiz-Salmeron R, et al. Role of thrombectomy and distal protection devices in acute myocardial infarction. Is their routine use of clinical benefit? A meta-analysis. Eur Heart J. 2006;27:770-1. [pmid: 16449246].
Salazar H, Masotti M, Kiamco R, et al. Role of thrombectomy and distal protection devices in acute myocardial infarction. Is their routine use of clinical benefit? A meta-analysis. Circulation. 2006;114:516.
Qayyum R, Khalid MR, Adomaityte J, et al. Distal protection devices during percutaneous coronary intervention are effective in reducing death or recurrent myocardial infarction in saphenous vein grafts but not in acute myocardial infarction: A meta-analysis. J Am Coll Cardiol. 2006;47:251A-2A.
Masotti M, Salazar H, Freixa X, et al. Role of embolic protection devices in acute myocardial infarction. Is their routine use of clinical benefit at 6 months?. Circulation. 2008;118:E431.
Masotti M, Salazar H, Kiamco R, et al. Embolic Protection Devices in Acute Myocardial Infarction. Do They Confer the Same Clinical Benefit?. Circulation. 2008;118:S974.
Salazar H, Freixa X, Bellera N, et al. Role of embolic protection devices in acute myocardial infarction. Is their routine use of clinical benefit at six months?. J Am Coll Cardiol. 2008;51:A208.
Mongeon FP, Belisle P, Joseph L, et al. Adjunctive thrombectomy for acute myocardial infarction: A bayesian meta-analysis. Circ Cardiovasc Interv. 2010;3:6-16. [pmid: 20118149].