# Baseline and Procedural Characteristics of Included Trials and Studies

Table 15 Baseline characteristics of randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Dudek, 2010 | Diver CE | 100 | 60.8 (10.2) | 80 | 96.9 | --- | 2 | --- | 0 | 39 | --- | 13 | 58 | 43 | 63 | 33
Dudek, 2010 | Control | 96 | 58.8 (10.3) | 81.7 | 97.9 | --- | 0 | --- | 0 | 39.6 | --- | 9.6 | 54 | 48.5 | 63 | 26
Liistro, 2009 | Export Thrombectomy Catheter | 55 | 64 (11) | 78 | 69 | 189 (105) | 0 | --- | 0 | 38 | --- | 20 | 60 | 34 | 63 | 38
Liistro, 2009 | Control | 56 | 65 (11) | 77 | 76 | 209 (147) | 0 | --- | 0 | 46 | --- | 12 | 53 | 30 | 64 | 23
Lipiecki, 2009 | Export Catheter | 20 | 59 (13) | 60 | 100 | 426 (294) | 0 | --- | 15 | 35 | --- | 5 | 25 | 30 | 35 | ---
Lipiecki, 2009 | Control | 24 | 59 (13) | 75 | 95.83 | 444 (408) | 0 | --- | 8 | 46 | --- | 8 | 33 | 21 | 38 | ---
Moura, 2009 | TAC | 76 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Moura, 2009 | Control | 76 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Sardella, 2009 | Export Medtronic (EM) | 88 | 66.7 (14.1) | 64.7 | 100 | 372 (54) | 0 | 43.18 | 0 | 43.2 | 100 | 23.8 | 67.0 | --- | 48.8 | 29.5
Sardella, 2009 | Control | 87 | 64.6 (12.5) | 55.1 | 100 | 366 (108) | 0 | 42.53 | 0 | 43.7 | 100 | 18.4 | 49.4 | --- | 26.4 | 36.8
Chao, 2008 | Export Aspiration Catheter | 37 | 60 (13) | 83.78 | --- | 312 (183) | 11 | 60 | 0 | 56.76 | 81 | 32 | 57 | 60 | 41 | ---
Chao, 2008 | Control | 37 | 62 (11) | 86.49 | --- | 331 (175) | 3 | 65 | 0 | 59.46 | 73 | 22 | 57 | 57 | 46 | ---
Chevalier, 2008 | Export Aspiration Catheter | 120 | 59.2 (12.8) | 80.8 | 99.2 | 321.7 (413.5) | 10.83 | --- | 0 | 47.5 | --- | 16.7 | 41.4 | 36.7 | 42.5 | 32.5
Chevalier, 2008 | Control | 129 | 61.2 (12.9) | 81.4 | 100 | 271.4 (197.6) | 10.85 | --- | 0 | 51.9 | --- | 13.2 | 44.2 | 41.9 | 35.7 | 25.6
Ciszewski, 2008 | Rescue/Diver | 65 | 64.3(12.4)^†^ | 65.19^†^ | --- | --- | --- | 32.28 † | 0 | --- | --- | --- | --- | --- | --- | ---
Ciszewski, 2008 | Control | 70 | | | --- | --- | --- | | 0 | --- | --- | --- | --- | --- | --- | ---
Ikari, 2008 | TVAC | 180 | 63.2 (10.6) | 80.6 | 74.6 | 270 (300) | --- | --- | 0 | 50.3 | 81.11 | 23.3 | 54.8 | 50.0 | 56.6 | 13.9
Ikari, 2008 | Control | 175 | 63.5 (9.9) | 77.7 | 75.3 | 312 (330) | --- | --- | 0 | 52.0 | 82.29 | 29.9 | 59.0 | 48.5 | 50.9 | 14.4
Svilaas, 2008 | 6F Export Aspiration Catheter | 535 | 63 (13) | 67.9 | 54.8 | 190 (110-270)^‡^ | 9.5 | --- | 0 | 42.9 | 48.6^§^ | 10.6 | 33.1 | 23.7 | 46.0 | 46.2
Svilaas, 2008 | Control | 536 | 63 (13) | 73.1 | 59.5 | 185 (107-263)^‡^ | 10.7 | --- | 0 | 43.1 | 44.0^§^ | 12.6 | 37.1 | 27.1 | 48.0 | 44.6
DeLuca, 2006 | Diver CE | 38 | 66.7 (14.1) | 71 | 100 | 432 (114) | 0 | --- | 0 | 97.4 | 100 | 23.7 | 39.5 | --- | 18.4 | 13.1
DeLuca, 2006 | Control | 38 | 64.6 (12.5) | 55.3 | 100 | 456 (108) | 0 | --- | 0 | 100 | 100 | 18.4 | 50 | --- | 26.3 | 36.8
Kaltoft, 2006 | Rescue Catheter | 108 | 65 (11) | 76 | 68 | 242 (171-321)^‡^ | 13 | 46.30 | 0 | 46 | 69 | 8 | 31 | 9 | 55 | ---
Kaltoft, 2006 | Control | 107 | 63 (13) | 80 | 69 | 208 (155-329)^‡^ | 10 | 42.99 | 0 | 43 | 79 | 6 | 21 | 9 | 64 | ---
Lee, 2006 | Export Aspiration Catheter | 67 | 60.8(1.05)^†^ | 69.9^†^ | --- | --- | --- | --- | 0 | 42.9^†^ | --- | --- | --- | --- | --- | ---
Lee, 2006 | Control | 66 | | | --- | --- | --- | --- | 0 | | --- | --- | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | 74 | 57.3 (13) | 84 | 81 | 206 (115) | 0 | 42 | 0 | 43 | --- | 21 | 37 | 34 | 54 | ---
Silva-Orrego, 2006 | Control | 74 | 58.9 (14) | 76 | 73 | 199 (124) | 0 | 51 | 0 | 51 | --- | 15 | 46 | 25 | 60 | ---
Burzotta, 2005 | Diver CE | 50 | 61 (13) | 90.0 | 86 | 274 (137) | --- | 40.0 | 32.0 | 40.0 | --- | 22.0 | 62.0 | 54.0 | 62.0 | 30.0
Burzotta, 2005 | Control | 49 | 60 (13) | 77.6 | 89.8 | 300 (202) | --- | 51.0 | 24.5 | 51.0 | --- | 18.4 | 57.1 | 34.7 | 53.1 | 22.4
Noel, 2005 | Export | 24 | 61.2(11.3)^†^ | --- | 100∥ | 282 (186)^†^ | --- | 44 † | --- | --- | --- | --- | --- | --- | --- | ---
Noel, 2005 | Control | 26 | | --- | 100∥ | | --- | | --- | --- | --- | --- | --- | --- | --- | ---
Dudek, 2004 | Rescue System | 40 | 56.7 (8.1) | 80 | 79 | 258 (198) | 15 | 40 | 0 | --- | --- | 10 | 75 | --- | 45 | 40
Dudek, 2004 | Control | 32 | 59.1 (7.8) | 69 | 66 | 236 (162) | 25 | 56 | 0 | --- | --- | 19 | 81 | --- | 31 | 50

* Symptom onset to balloon, ischemic time, symptom to randomization,symptom onset to hospital, symptom onset to laboratory, symptom onset to angiography, symptom onset to admission, symptom onset to procedure;

† Mean for the total study population;

‡ Median (interquartile range);

§ % of visible thrombi out of all thrombi;

∥ TIMI<3

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TAC=thrombectomy aspiration catheter; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis; TVAC = transvascular aspiration catheter

Table 16 Procedural characteristics of randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Dudek, 2010 | Diver CE | 100 | --- | 99/100 (99) | 75/100 (75) | 62/100 (62) | Aspirin 325mg and clopidogrel 600mg pre-PCI | Heparin 70 U/kg pre-PCI
Dudek, 2010 | Control | 96 | --- | 93/96 (96.8) | 5/96 (5.2) | 60/96 (63)
Liistro, 2009 | Export Thrombectomy Catheter | 55 | 75.7 (30.0) | 55/55 (100) | 12/55 (21) | 55/55 (100) | Aspirin 500 mg and clopidogrel 600 mg load pre-PCI | Heparin 70 IU/kg pre-PCI
Liistro, 2009 | Control | 56 | 75.9 (38.7) | 56/56 (100) | 5/56 (9) | 56/56 (100)
Lipiecki, 2009 | Export Catheter | 20 | --- | 19/20 (95) | 10/20 (55) | 5/20 (25) | Aspirin and clopidogrel 300 mg load pre-PCI | Heparin pre-PCI
Lipiecki, 2009 | Control | 24 | --- | 22/24 (92) | 6/24 (33) | 15/24 (62)
Moura, 2009 | TAC | 76 | --- | --- | --- | 45/76 (59) | --- | ---
Moura, 2009 | Control | 76 | --- | --- | --- | 62/76 (82) | --- | ---
Sardella, 2009 | Export Medtronic (EM) | 88 | --- | 88/88 (100) | 67/88 (76.2) | 88/88 (100) | Aspirin 300 mg and clopidogrel 300 mg pre-PCI | Heparin 7.5 UI pre-PCI
Sardella, 2009 | Control | 87 | --- | 87/87 (100) | 2/87 (2.3) | 87/87 (100) | Aspirin and clopidogrel (for 12 m) post-PCI
Chao, 2008 | Export Aspiration Catheter | 37 | 49 (18)^†^ | 35/37 (95) | 19/37 (51) | 7/37 (19) | Aspirin 300 mg and clopidogrel 300 mg load pre-PCI | Heparin 70-100 IU/kg IV (ACT >200 s) pre-PCI and for at least 24 hours
Chao, 2008 | Control | 37 | 53 (23)^†^ | 34/37 (92) | 4/37 (11) | 12/37 (32 | Aspirin 100 mg/d indefinitely and clopidogrel 75 mg/d for 3 m post-PCI
Chevalier, 2008 | Export Aspiration Catheter | 120 | 36.7 (18.0) | 120/120 (100) | --- | --- | Aspirin and clopidogrel used at investigator's discretion | Heparin used at investigator's discretion
Chevalier, 2008 | Control | 129 | 34.5 (21.5) | 129/129 (100) | --- | ---
Ciszewski, 2008 | Rescue/Diver | 65 | --- | 65/65 (100) | --- | --- | --- | ---
Ciszewski, 2008 | Control | 70 | --- | 70/70 (100) | --- | --- | --- | ---
Ikari, 2008 | TVAC | 178 | 87.0 (32.4) | 167/178 (94.1) | --- | 0/178 (0) | Aspirin pre-PCI Ticlopidine (cilostizol if intolerant to ticlopidine) and aspirin post-PCI | Heparin (ACT≥300 s) pre-PCI
Ikari, 2008 | Control | 180 | 93.6 (78.6) | 160/171 (93.4) | --- | 0/180 (0)
Svilaas, 2008 | 6F Export Aspiration Catheter | 535 | 28 (14-42)^*^ | 442/279 (92.3) | 295/535 (55.1) | 469/502 (93.4) | Aspirin 500 mg bolus and clopidogrel 600mg pre-PCI and standard aspirin and clopidogrel therapy post-PCI | Heparin 5000 IU pre-PCI plus additional doses based on ACT
Svilaas, 2008 | Control | 536 | 26 (12-40)^*^ | 438/476 (92.0) | --- | 452/503 (89.9)
DeLuca, 2006 | Diver CE | 38 | --- | 38/38 (100) | 35/38 (92.1) | --- | Aspirin 300 mg pre-PCI and 100 mg/d post-PCI and ticlopidine 250 mg BID for at least 4 weeks or clopidogrel 300 mg followed by 75 mg/d for at least 4 weeks | Heparin 8000 IU IV pre-PCI continued for 48 hours post-PCI
DeLuca, 2006 | Control | 38 | --- | 38/38 (100) | 2/38 (5.3) | ---
Kaltoft, 2006 | Rescue Catheter | 108 | 39 (29-48)^*^ | 103/108 (95) | --- | 104/108 (96) | Aspirin 300 mg and clopidogrel 300 mg pre-PCI Aspirin 75 mg/d and clopidogrel 75 mg/d for 12 m post-PCI | Heparin 10,000 IE IV pre-PCI
Kaltoft, 2006 | Control | 107 | 29 (23-38)^*^ | 104/107 (97) | --- | 100/107 (93)
Lee, 2006 | Export Aspiration Catheter | 67 | --- | --- | --- | --- | --- | ---
Lee, 2006 | Control | 66 | --- | --- | --- | --- | --- | ---
Silva-Orrego, 2006 | Pronto Extraction Catheter | 74 | 57 (19) | 73/74 (99) | 52/74 (70) | 74/74 (100) | Aspirin pre-PCI | Heparin 60 U/kg pre-PCI
Silva-Orrego, 2006 | Control | 74 | 54 (21) | 72/74 (97) | 18/74 (24) | 74/74 (100)
Burzotta, 2005 | Diver CE | 50 | 81 (43) | --- | 33/50 (66.0) | 34/50 (68.0) | Aspirin and clopidogrel (300 mg load followed by 75 mg/d) for at least 4 weeks | Heparin (ACT 250-300 s)
Burzotta, 2005 | Control | 49 | 72 (34) | --- | 12/49 (24.4) | 31/49 (63.3)
Noel, 2005 | Export | 24 | --- | --- | --- | --- | --- | ---
Noel, 2005 | Control | 26 | --- | --- | --- | --- | --- | ---
Dudek, 2004 | Rescue System | 40 | --- | --- | --- | --- | Aspirin 75 mg/d, clopidogrel (initially 300 mg, followed by 75 mg/d) or ticlopidine (500 mg/d) for 1 m | ---
Dudek, 2004 | Control | 32 | --- | --- | --- | --- | | ---

* Median (interquartile range);

† Lab to TIMI-3

Abbreivations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IU=international units; IV=intravenous; kg=kilogram; m=months; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; TAC=thrombectomy aspiration catheter; TVAC=transvascular aspiration catheter; U=units

Table 17 Baseline characteristics of randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Age (SD) | Male (%) | TIMI -0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Migliorini 2010 | AngioJet Rheolytic Thrombect my | 256 | 63.0 (12.3) | 76 | 83.5 | 125 (85-221.5)^†^ | 3.9 | 39 | 0 | 42 | --- | 14 | 47 | 30 | --- | ---
Migliorini 2010 | Control | 245 | 64.3 (11.5) | 81 | 83.9 | 135 (86-227)^†^ | 4.9 | 37 | 0 | 37 | --- | 15 | 47 | 35 | --- | ---
Ali, 2006 | AngioJet Catheter | 240 | 60 (51.0-69.0)^†^ | 75.8 | 68.4 | 144 (198) | --- | --- | 14.2 | 38.9 | 20.83 | 16.7 | 42.9 | 22.1 | 44.2 | ---
Ali, 2006 | Control | 240 | 59.9 (49.0 -70.0)^†^ | 74.2 | 63.2 | 150 (192) | --- | --- | 13.3 | 37.4 | 19.19 | 15.8 | 42.1 | 25.4 | 45.0 | ---
Lefèvre 2005 | X-Sizer Catheter | 100 | 61 (13) | 76 | 100 | 251 (151) | 10 | 54 | 0 | 55 | --- | 25 | 54 | 58 | 52 | ---
Lefèvre 2005 | Control | 101 | 62 (11) | 73 | 100 | 264 (194) | 6 | 50 | 0 | 48 | --- | 18 | 50 | 61 | 51 | ---
Antoniucci 2004 | AngioJet | 50 | 63 (13) | 82 | 76 | 234 (120) | --- | 34 | 0 | 34 | --- | 18 | 36 | 46 | 38 | ---
Antoniucci 2004 | Control | 50 | 66 (12) | 78 | 80 | 264 (168) | --- | 46 | 0 | 46 | --- | 16 | 38 | 48 | 28 | ---
Napodano 2003 | X-Sizer Catheter | 46 | 61.3 (10.8) | 82.6 | 73.9 | 202.9 (204.9) | 17.4 | 39.1 | --- | --- | 100 | 13.0 | 60.9 | 50.0 | 45.6 | ---
Napodano 2003 | Control | 46 | 63.6 (11.7) | 71.7 | 84.7 | 165.7 (134.7) | 6.5 | 43.5 | --- | --- | 100 | 13.0 | 65.2 | 52.1 | 34.8 | ---

* Symptom onset to emergency room, symptom onset to angiogram, time to treatment, symptom onset to hospital;

† Median (interquartile range)

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 18 Procedural characteristics of randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Migliorini, 2010 | AngioJet Rheolytic Thrombectmy | 256 | 59.5 (44.7-70)^*^ | 256/256 (100) | 256/256 (100) | 249/256 (97) | Aspirin 325 mg po or 500 mg IV and clopidogrel 600 mg load pre-PCI or immediately post-PCI | Heparin 70 U/kg bolus with additional doses (ACT 200-250 s)
Migliorini, 2010 | Control | 245 | 46 (35-60)^*^ | 245/245 (100) | 245/245 (100) | 239/245 (98) | Aspirin 100 to 325 mg/d indefinitely and clopidogrel 75 mg/d for 6 m post-PCI
Ali, 2006 | AngioJet Catheter | 240 | 75.4 (30.9) | 224/240 (93.7) | --- | 228/240 (95.0) | Aspirin 325 mg and clopidogrel 300 mg load then 75 mg/d for at least 4 weeks (ticlopidine 500mg load then 250 BID if intolerant to clopidogrel) | Heparin during PCI (ACT >250 s)
Ali, 2006 | Control | 240 | 59.2 (26.8) | 227/240 (94.5) | --- | 226/240 (94.2)
Lefèvre, 2005 | X-Sizer Catheter | 100 | 54 (28) | 100/100 (100) | 60/100 (60) | 55/100 (55) | Aspirin pre-PCI | Heparin 70 U/kg (ACT >250 s)
Lefèvre, 2005 | Control | 101 | 45 (25) | 100/101 (99) | 34/101 (34) | 66/101 (65)
Antoniucci, 2004 | AngioJet | 50 | --- | 49/50 (98) | 47/50 (94) | 49/50 (98) | Aspirin 325 mg/d indefinitely and ticlopidine (500 mg/d for 1 m) or clopidogrel (75 mg/d for 1 m) | Heparin 70 U/kg bolus and additional doses (ACT 200-300 s)
Antoniucci, 2004 | Control | 50 | --- | 49/50 (98) | 41/50 (82) | 49/50 (98)
Napodano, 2003 | X-Sizer Catheter | 46 | --- | 43/46 (93.5) | 28/46 (60.8) | 20/46 (43.4) | Aspirin 250-500 mg IV pre-PCI/during PCI and 100-375 mg/d indefinitely post-PCI | Heparin 70 U/kg IV pre-PCI/ during PCI and 7-12 IU/kg/hour for 48 hours (ACT >250 s)
Napodano, 2003 | Control | 46 | --- | 42/46 (91.3) | 13/46 (28.3) | 19/46 (41.3) | Ticlopidine 250 mg twice/d pre-PCI/during PCI and post-PCI Clopidogrel 75 mg/d pre-PCI/during PCI and post-PCI for 1 m

* Median (interquartile range)

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IU=international units; IV=intravenous; kg=kilogram; m=months; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; po=by mouth; s=seconds; SD=standard deviation; U=units

Table 19 Baseline characteristics of randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Ito, 2010 | Filtrap | 19 | 62.7 (12) | 79 | 89 | 275 (223) | 0 | 100 | 0 | --- | --- | 47 | 58 | 74 | 68 | ---
Ito, 2010 | Control | 17 | 63.7 (8.4) | 76 | 94 | 196 (223) | 0 | 100 | 0 | --- | --- | 29 | 53 | 59 | 71 | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | 312 | 62 (12.3) | 74.4 | 67 | 200 (26-1350)^†^ | 6.4 | --- | 0 | 44 | 68 | 9.0 | 32.1 | 18.6 | 56.7 | 36.5
Kelbæk, 2008 | Control | 314 | 63 (12.1) | 72.0 | 68 | 199 (40-996)^†^ | 6.4 | --- | 0 | 38 | 75 | 11.8 | 34.1 | 20.4 | 50.3 | 37.6
Cura, 2007 | SpideRX | 70 | 60.2 (9.9) | 86 | 85 | 150 (80-270)^†^ | 21 | --- | 3 | 53 | 90 | 19 | 56 | --- | 33 | ---
Cura, 2007 | Control | 70 | 60.4 (10.4) | 77 | 83 | 146 (75-236)^†^ | 13 | --- | 4 | 56 | 97 | 20 | 49 | --- | 47 | ---
Guetta, 2007 | FilterWire EZ | 51 | 60 (12) | 82 | 78 | 180 (90-420)^†^ | 12 | --- | --- | 51 | --- | 22 | 44 | 48 | 43 | ---
Guetta, 2007 | Control | 49 | 57 (10) | 82 | 92 | 120 (66-180)^†^ | 11 | --- | --- | 53 | --- | 23 | 51 | 50 | 44 | ---
Lefèvre, 2004 | AngioGuardXP | 32 | 61 (15) | 81 | 71.88 | --- | --- | --- | --- | 41 | 100 | 19 | 50 | 62 | --- | ---
Lefèvre, 2004 | Control | 28 | 62 (12) | 83 | 67.86 | --- | --- | --- | --- | 53 | 100 | 14 | 43 | 61 | --- | ---

* Symptom onset to hospital, symptom onset to angiography, symptom onset to emergency room;

† Median (interquartile range)

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 20 Procedural characteristics of randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Ito, 2010 | Filtrap | 19 | --- | 19/19 (100) | --- | --- | Aspirin 200mg and ticopidine 200mg or clopidogrel 300mg pre-PCI | Heparin 8000 U IV pre-PCI
Ito, 2010 | Control | 17 | --- | 17/17 (100) | --- | ---
Kelbæk, 2008 | FilterWire-EZ or SpiderX protection device | 312 | --- | 307/312 (98) | --- | 301/312 (97) | Aspirin 300-500 mg and clopidogrel 300-600 mg pre-PCI | Heparin 10,000 IU pre-PCI
Kelbæk, 2008 | Control | 314 | --- | 312/314 (99) | --- | 302/314 (96) | Clopidogrel continued for 1 year and aspirin continued indefinitely
Cura, 2007 | SpideRX | 70 | 52 (43-70)^*^ | 69/70 (99) | --- | 18/70 (26) | Aspirin 325 mg and clopidogrel 300-600 mg load pre- or immediately after PCI | Heparin IV during PCI (ACT>250 s)
Cura, 2007 | Control | 70 | 43.5 (30-54)^*^ | 68/70 (97) | --- | 18/70 (26) | Clopidogrel recommended for 12 m and aspirin indefinitely post-PCI
Guetta, 2007 | FilterWire EZ | 51 | --- | --- | --- | 38/51 (74) | Aspirin 500 mg IV or 200 mg orally and clopidogrel 300 mg load pre-PCI | Heparin 70 U/kg pre-PCI
Guetta, 2007 | Control | 49 | --- | --- | --- | 38/49 (77)
Lefèvre, 2004 | AngioGuardXP | 32 | --- | 32/32 (100) | --- | --- | --- | ---
Lefèvre, 2004 | Control | 28 | --- | 28/28 (100) | --- | --- | --- | ---

* Median (interquartile range)

Abbreivations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IU=international units; IV=intravenous; kg=kilogram; m=months; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; TAC=thrombectomy aspiration catheter; TVAC=transvascular aspiration catheter; U=units

Table 21 Baseline characteristics of randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Duan, 2010 | PercuSurge Guardwire Plus | 46 | 55 (7) | 86.96 | 80.4 | 289 (58) | --- | 100 | 0 | 100 | --- | 6.5 | 17.4 | 15.2 | 63.0 | ---
Duan, 2010 | Control | 50 | 56 (8) | 82 | 80.0 | 282 (60) | --- | 100 | 0 | 100 | --- | 8.0 | 20.0 | 20.0 | 58.0 | ---
Pan, 2010 | PercuSurge Guardwire | 52 | 67 (6.1)^‡^ | 61.54^‡^ | 73.1 | 157 (47) | 0 | 40.4^‡^ | --- | 55.8 | --- | 32.7 | 55.8 | --- | 42.3 | ---
Pan, 2010 | Control | 52 | | | 71.1 | 161 (43) | 0 | | --- | 51.9 | --- | 30.7 | 51.9 | --- | 46.2 | ---
Tahk, 2008 | PercuSurge GuardWire | 60 | 55.9 (13.9) | 85 | 67 | 339.3 (189.2) | 0 | 53 | 0 | 53 | --- | 20 | 36 | --- | 68 | ---
Tahk, 2008 | Control | 56 | 58.8 (14.5) | 71 | 76 | 327.8 (209.5) | 0 | 56 | 0 | 56 | --- | 21 | 54 | --- | 57 | ---
Hahn, 2007 | GuardWire | 19 | 55 (45-62)^†^ | 79 | 95 | 212 (160-325)^†^ | --- | 58 | 0 | 58 | --- | 32 | 47 | 26 | 63 | ---
Hahn, 2007 | Control | 20 | 56 (45-65)^†^ | 95 | 75 | 248 (185-480)^†^ | --- | 55 | 0 | 55 | --- | 15 | 25 | 20 | 65 | ---
Matsuo, 2007 | GuardWire Distal Protection System | 80 | 65 (12) | 86 | 78 | 312 (252) | 5 | --- | --- | 57 | --- | 20 | 51 | 35 | 47 | 12
Matsuo, 2007 | Control | 74 | 65 (13) | 76 | 71 | 264 (174) | 8 | --- | --- | 40 | --- | 25 | 49 | 39 | 50 | 7
Muramatsu, 2007 | GuardWire Plus System | 173 | 63.5 (12.3) | 78.6 | 69 | 252 (168) | 1.7 | --- | 0 | 50 | --- | 31.8 | 42.2 | 32.9 | 51.4 | 4.6
Muramatsu, 2007 | Control | 168 | 64.7 (11.1) | 72.9 | 68 | 264 (204) | 2.9 | --- | 0 | 48 | --- | 32.3 | 44.1 | 32.9 | 49.4 | 4.1
Zhou, 2007 | PercuSurge GuardWire | 52 | 55 (14) | 62 | 100 | 310 (145) | --- | --- | 0 | 54 | --- | 23 | 37 | --- | 67 | ---
Zhou, 2007 | Control | 60 | 57 (15) | 67 | 100 | 315 (176) | --- | --- | 0 | 48 | --- | 22 | 35 | --- | 60 | ---
Okamura, 2005 | PercuSurge GuardWire | 8 | 59 (13) | 75 | 75 | 450 (348) | --- | --- | --- | 25 | --- | 25 | 38 | 38 | 75 | ---
Okamura, 2005 | Control | 8 | 59 (8) | 88 | 38 | 510 (492 | --- | --- | --- | 75 | --- | 25 | 63 | 38 | 63 | ---
Stone, 2005 | GuardWire Plus | 252 | 58.5(51.1-69.3)^†^ | 76.2 | 64.0 | 233 (178-296)^†^ | 9.5 | --- | 18.3 | 40.2 | 72.1 | 7.5 | 35.9 | 20.2 | 40.5 | ---
Stone, 2005 | Control | 249 | 59.8 (52.1-69.3)^†^ | 80.7 | 67.8 | 211 (158-273)^†^ | 12.4 | --- | 18.9 | 38.5 | 72.1 | 17.3 | 38.2 | 28.5 | 44.6 | ---

* Symptom onset to stenting, symptom onset to balloon, symptom onset to hospital arrival, symptom onset to reperfusion, elapsed time before reperfusion;

† Median (interquartile range);

‡ total study population

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 22 Procedural characteristics of randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Duan, 2010 | PercuSurge Guardwire Plus | 46 | --- | 46/46 (100) | --- | --- | Aspirin 300mg and clopidogrel 300mg followed by 75mg pre-PCI | UFH 70U/kg to achieve an ACT of 300s
Duan, 2010 | Control | 50 | --- | 50/50 (100) | --- | ---
Pan, 2010 | PercuSurge Guardwire | 52 | --- | --- | --- | 52/52 (100) | Aspirin 300mg and clopidogrel 300mg pre-PCI | ---
Pan, 2010 | Control | 52 | --- | --- | --- | 52/52 (100) | | ---
Tahk, 2008 | PercuSurge GuardWire | 60 | --- | 60/60 (100) | 0/60 (0) | --- | Aspirin 300 mg and clopidogrel 300-600 mg pre-PCI | Heparin IV during PCI (ACT 300 s)
Tahk, 2008 | Control | 56 | --- | 56/56 (100) | 1/56 (1.8) | ---
Hahn, 2007 | GuardWire | 19 | --- | 19/19 (100) | --- | 1/19 (5.3) | Appropriate antiplatelet therapy | Heparin
Hahn, 2007 | Control | 20 | --- | 29/20 (100) | --- | 1/20 (5.0)
Matsuo, 2007 | GuardWire Distal Protection System | 80 | 75.8 (30) | --- | --- | 9/80 (11) | Aspirin 100 mg and ticlopidine 200 mg pre-PCI | Heaparin 5000 U (ACT >250 s)
Matsuo, 2007 | Control | 74 | 53 (25) | --- | --- | 5/74 (7)
Muramatsu, 2007 | GuardWire Plus System | 173 | 29.7 (18.3)^*^ | 173/173 (100) | --- | --- | Aspirin 81-100 mg/d and ticlopidine 200 mg/d for at least 2 weeks | ---
Muramatsu, 2007 | Control | 168 | 29.5 (18.2)^*^ | 168/168 (100) | --- | --- | | ---
Zhou, 2007 | PercuSurge GuardWire | 52 | --- | 52/52 (100) | --- | 0/52 (0) | Aspirin 300 mg and clopidogrel 300 mg pre-PCI then aspirin 100 mg/d and clopidogrel 75 mg/d post-PCI | Heparin IV during PCI (ACT ≥300 s)
Zhou, 2007 | Control | 60 | --- | 60/60 (100) | --- | 0/60 (0)
Okamura, 2005 | PercuSurge GuardWire | 8 | --- | 8/8 (100) | --- | --- | Aspirin 243 mg at least 30 min pre-PCI | Heparin 100 U/kg IV
Okamura, 2005 | Control | 8 | --- | 8/8 (100) | --- | ---
Stone, 2005 | GuardWire Plus | 252 | 53 (42-69)^†^ | 244/252 (96.8) | --- | 210/252 (83.3) | Aspirin 324 mg and clopidogrel 300 mg pre-PCI | Heparin IV 70 U/kg bolus (ACT >300 s pre-PCI or 200-300 s if GP2B3Ai used)
Stone, 2005 | Control | 249 | 39 (29-51)^†^ | 241/249 (96.8) | --- | 208/249 (83.5)

* Operation time;

† Median (interquartile range)

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IV=intravenous; kg=kilogram; mg=milligram; min=minutes; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; U=units

Table 23 Baseline characteristics of randomized controlled trials evaluating proximal balloon embolic protection versus control in patients with ST-segment elevation myocardial infarction

Study Year | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Haeck, 2009 | Proxis | 141 | 62 (11) | 80 | 98.58 | 170 (132-234)^†^ | 6 | --- | 0 | 29 | 76 | 12 | 31 | 21 | 50 | 35
Haeck, 2009 | Control | 143 | 59 (11) | 80 | 96.50 | 153 (126-212)^†^ | 9 | --- | 0 | 29 | 66 | 6 | 23 | 13 | 65 | 38

* Symptom onset to balloon;

† Median (interquartile range)

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 24 Procedural characteristics of randomized controlled trials evaluating proximal balloon embolic protection versus control in patients with ST-segment elevation myocardial infarction

Study, Year | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Haeck, 2009 | Proxis | 141 | 45 (36-58)^*^ | --- | 15/141 (11) | 61/141(43) | Aspirin 300 mg pre-PCI and at least 80 mg/d post-PCI and clopidogrel 600 mg load pre-PCI followed by 75 mg/d post-PCI | Heparin 70 U/kg pre-PCI
Haeck, 2009 | Control | 143 | 31 (25-40)^*^ | --- | 27 /143 (19) | 50/143 (35)

* Median (interquartile range)

Abbreviations: d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; kg=kilogram; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; SD=standard deviation; U=units

Table 25 Baseline characteristics of randomized controlled trials evaluating thrombectomy or embolic protection devices versus cotnrol in patients with mixed acute coronary syndrome

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Parikh 2008 | Distal Balloon Embolic Protection | GuardWire | 30 | 55.17 (12) | 90 | --- | --- | --- | --- | --- | 53 | 100 | 20 | 20 | 3 | 17 | 23
Parikh 2008 | Distal Balloon Embolic Protection | Control | 37 | 56.16 (11.31) | 95 | --- | --- | --- | --- | --- | 62 | 100 | 41 | 28 | 8 | 19 | 27
Gick 2005 | Distal Filter Embolic Protection | FilterWire | 100 | 62.9 (11.3) | 86 | 65 | 372 (210-726)^†^ | 12 | --- | --- | 45 | --- | 21 | 65 | --- | 35 | ---
Gick 2005 | Distal Filter Embolic Protection | Control | 100 | 60.2 (13.0) | 80 | 57 | 474 (266-936)^†^ | 17 | --- | --- | 39 | --- | 26 | 69 | --- | 35 | ---
Sardella 2005 | Catheter Aspiration | Diver CE | 28 | 65.3 (11.2)^‡^ | 77.42^‡^ | --- | 408 (138)^‡^ | --- | 100 | 0 | --- | 100 | --- | 78 | --- | --- | ---
Sardella 2005 | Catheter Aspiration | Control | 34 | | | --- | | --- | 100 | 0 | --- | 100 | --- | 55 | --- | --- | ---
Kunii 2004 | Catheter Aspiration | Rescue PT | 129 | 64 (11.8) | 79.84 | --- | --- | --- | --- | 0 | 34.1 | --- | --- | --- | --- | --- | ---
Kunii 2004 | Catheter Aspiration | Control | 129 | 65.9 (11.1) | 79.84 | --- | --- | --- | --- | 0 | 45.8 | --- | --- | --- | --- | --- | ---
Nanasato 2004 | Distal Balloon Embolic Protection | GuardWire | 34 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nanasato 2004 | Distal Balloon Embolic Protection | Control | 30 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Matsushita 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | 24 | 63 (13) | 83.33 | --- | --- | 0 | 100 | --- | --- | --- | --- | --- | --- | --- | ---
Matsushita 2003 | Distal Balloon Embolic Protection | Control | 56 | 63 (10) | 76.79 | --- | --- | 0 | 100 | --- | --- | --- | --- | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | 30 | 55.9 (9.9) | 73 | 80.00 | 291 (177) | 10 | 35 | 23 | 30 | --- | 17 | 53 | 60 | 57 | ---
Beran, 2002 | Mechanical Thrombectomy | Control | 31 | 53.9 (10.0) | 77 | 74.19 | 279 (185) | 10 | 35 | 10 | 32 | --- | 13 | 36 | 58 | 55 | ---

* Symptom onset to balloon, symptom onset to percutaneous coronary intervention;

† Median (interquartile range);

‡ Mean for the total study population

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 26 Procedural characteristics of randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with mixed acute coronary syndrome

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Parikh, 2008 | Distal Balloon Embolic Protection | GuardWire | 30 | 25.01 (11.89) | --- | 10/30 (33) | 13/30 (43) | --- | ---
Parikh, 2008 | Distal Balloon Embolic Protection | Control | 37 | 31.98 (15.33) | --- | 3/37 (8) | 26/37 (70) | --- | ---
Gick, 2005 | Distal Filter Embolic Protection | FilterWire | 100 | --- | --- | --- | --- | Aspirin 500 mg IV and clopidogrel 600 mg load pre-PCI | Heparin 100 U/kg pre-PCI
Gick, 2005 | Distal Filter Embolic Protection | Control | 100 | --- | --- | --- | ---
Sardella, 2005 | Catheter Aspiration | Diver CE | 28 | --- | 28/28 (100) | --- | 28/28 (100) | --- | Heparin
Sardella, 2005 | Catheter Aspiration | Control | 34 | --- | 34/34 (100) | --- | 34/34 (100) | ---
Kunii, 2004 | Catheter Aspiration | Rescue PT | 129 | --- | 129/129 (100) | --- | --- | --- | ---
Kunii, 2004 | Catheter Aspiration | Control | 129 | --- | 129/129 (100) | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | GuardWire | 34 | --- | --- | --- | --- | --- | ---
Nanasato, 2004 | Distal Balloon Embolic Protection | Control | 32 | --- | --- | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | PercuSurge GuardWire | 24 | --- | --- | --- | --- | --- | ---
Matsushita, 2003 | Distal Balloon Embolic Protection | Control | 56 | --- | --- | --- | --- | --- | ---
Beran, 2002 | Mechanical Thrombectomy | X-sizer | 30 | --- | --- | 14/30 (46.67) | 22/30 (73) | STEMI or UA: Aspirin pre-PCI and 100 mg post-PCI and clopidogrel 600 mg immediately after stenting and then 75 mg/d for 30 d | STEMI: Heparin (ACT >300 s) pre-PCI and during intervention UA: low-molecular weight heparin pre-PCI and heparin during intervention (ACT >300 s)
Beran, 2002 | Mechanical Thrombectomy | Control | 31 | --- | --- | 2/31 (6.45) | 21/31 (68)

* Median (interquartile range)

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IV=intravenous; kg=kilogram; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; STEMI=ST-segment elevation myocardial infarction; U=units; UA=unstable angina

Table 27 Baseline characteristics of randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD) | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Webster 2008 | Distal Filter Embolic Protection | FilterWire EZ | 77 | 58 (11) | 83 | --- | --- | --- | --- | --- | 39 | --- | 16 | 39 | 69 | 71 | ---
Webster 2008 | Distal Filter Embolic Protection | Control | 74 | 60 (13) | 89 | --- | --- | --- | --- | --- | 32 | --- | 26 | 46 | 62 | 66 | ---
Dudek 2003 | Distal Filter Embolic Protection | AngioGuard | 15 | 59.4 (66.6) | 66.6 | --- | --- | 60 | --- | --- | --- | --- | 0 | 40 | 26.0 | --- | ---
Dudek 2003 | Distal Filter Embolic Protection | Control | 16 | 49.3 (8.4) | 62.5 | --- | --- | 50 | --- | --- | --- | --- | 0 | 62.5 | 31.0 | --- | ---

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 28 Procedural characteristics of randomized controlled trials evaluating thrombectomy or embolic protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Webster, 2008 | Distal Filter Embolic Protection | FilterWire EZ | 77 | --- | --- | --- | --- | --- | ---
Webster, 2008 | Distal Filter Embolic Protection | Control | 74 | --- | --- | --- | --- | --- | ---
Dudek, 2003 | Distal Filter Embolic Protection | AngioGuard | 15 | 63 (17) | 15/15 (100) | --- | --- | Aspirin 75 mg and ticlopidine 500 mg/d | Heparin 60 U/kg (ACT 200-300 s)
Dudek, 2003 | Distal Filter Embolic Protection | Control | 16 | --- | 16/16 (100) | --- | ---

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; kg=kilogram; mg=milligram; n=number; N=number of participants in the group; s=seconds; SD=standard deviation; U=units

Table 29 Baseline characteristics of direct comparative randomized controlled trials in ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Sardella 2008 | Catheter Aspiration | Diver Invatec catheter | 52 | 64.6 (12.5) | 78.8 | 100 | 414 (60) | 0 | --- | 0 | 46.1 | 100 | 26.9 | 63.4 | --- | 42.3 | 23.0
Sardella 2008 | Catheter Aspiration | Export Medtronic | 51 | 66.7 (14.1) | 78.4 | 100 | 408 (54) | 0 | --- | 0 | 41.2 | 100 | 23.5 | 66.6 | --- | 49.0 | 29.4
Yan 2007 | Catheter Aspiration | Diver CE catheter | 61 | 60 (14) | 82 | 100 | 350 (185) | --- | 0 | 0 | 0 | --- | 31 | 62 | 54 | 62 | 30
Yan 2007 | Distal Balloon Embolic Protection | GuardWire Plus | 61 | 60 (13) | 84 | 100 | 345 (180) | --- | 0 | 0 | 0 | --- | 28 | 57 | 56 | 61 | 23

* Symptom onset to balloon, Symptom onset to angiogram

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 30 Procedural characteristics of direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Sardella 2008 | Catheter Aspiration | Diver Invatec catheter | 52 | --- | 52/52 (100) | 32/52 (65.3) | 52/52 (100) | Aspirin 300 mg and clopidogrel 300 mg load pre-PCI and aspirin 100 mg/d and clopidogrel 75 mg/d (for 6 m) post-PCI | Heparin (ACT >250 s) and continued for 48 hours post-PCI
Sardella 2008 | Catheter Aspiration | Export Medtronic | 51 | --- | 51/51 (100) | 39/51 (76.4) | 51/51 (100)
Yan, 2007 | Catheter Aspiration | Diver CE catheter | 61 | 60 (24) | --- | 39/61 (64) | 7/61 (11) | Aspirin 300 mg and clopidogrel 300-600 mg pre-PCI | Heparin 8000-10000 U IV during PCI and low-molecular weight heparin for 1 week if needed post-PCI
Yan, 2007 | Distal Balloon Embolic Protection | GuardWire Plus | 61 | 65 (28) | --- | 41/61 (67) | 8/61 (13) | Aspirin 300 mg/d for 4 weeks then 100 mg/d and clopidogrel 75 mg/d for greater than 9-12 m

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIb IIIa inhibitor; IV=intravenous; m=months; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; U=units

Table 31 Baseline characteristics of randomized controlled trials with selective inclusion/exclusion criteria in patient with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Wita, 2009 | Catheter Aspiration | Diver CE | 19 | 56.6 (10.9) | 79 | 100 | 268 (197) | 0 | 100 | --- | 100 | --- | 5.3 | 42. | 10.5 | 68.4 | ---
Wita, 2009 | Catheter Aspiration | Control | 23 | 58.1 (10.8) | 70.9 | 100 | 323 (183) | 0 | 100 | --- | 100 | --- | 16.7 | 139.1 | 8.3 | 83.3 | ---
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | 25 | 68 (9) | 100 | --- | --- | 0 | 0 | 0 | --- | --- | 45 | 45 | 55 | 50 | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | 24 | 60 (18) | 100 | --- | --- | 0 | 0 | 0 | --- | --- | 45 | 50 | 65 | 55 | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | 28 | 66 (13) | 100 | --- | --- | 0 | 0 | 0 | --- | --- | 40 | 50 | 65 | 65 | ---

* Time to reperfusion

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 32 Procedural characteristics of randomized controlled trials with selective inclusion / exclusion criteria in patient with ST-segment elevation myocardial infarction

Study,Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Wita, 2009 | Catheter Aspiration | Diver CE | 19 | 39.5 (10.1) | 19/19 (100) | --- | 19/19 (100) | Aspirin and clopidogrel load pre-PCI | Heparin (ACT >200 s)
Wita, 2009 | Catheter Aspiration | Control | 23 | 32.3 (18.6) | 23/23 (100) | --- | 23/23 (100)
Ozaki, 2006 | Catheter Aspiration | Rescue or Thrombuster systems | 25 | --- | 25/25 (100) | --- | --- | Aspirin 162 mg and ticlopidine 200 mg pre-PCI and post-PCI | Heparin 10,000 U intra-arterial pre-PCI and 20,000 U/d IV post-PCI
Ozaki, 2006 | Distal Balloon Embolic Protection | PercuSurge GuardWire | 24 | --- | 24/24 (100) | --- | ---
Ozaki, 2006 | Distal Balloon Embolic Protection | Control | 28 | --- | 28/28 (100) | --- | ---

Abbreviations: ACT=activated clotting time; d=days; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IV=intravenous; mg=milligram; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; U=units

Table 33 Baseline characteristics of controlled observational studies

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Beaudoin, 2010 | Catheter aspiration | Export | 165 | 60 (11) | 76 | 88 | --- | 14 | 37 | 9.1 | --- | --- | 9 | 43 | 36 | 41 | ---
Beaudoin, 2010 | Catheter aspiration | Control | 370 | 61(13) | 70 | 62 | --- | 15 | 45 | 19.7 | --- | --- | 15 | 44 | 42 | 44 | ---
Kim, 2010 | Thrombus Aspiration | Thrombus Aspiration | 429 | 62 (13) | 77.6 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kim, 2010 | Thrombus Aspiration | Control | 429 | 62 (13) | 72.7 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Distal Protection Device | 1050^†^ | 58(12)^‡^ | 72.5^‡^ | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Ko, 2009 | Distal Embolic Protection | Control | | | | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Aspiration Catheter | 381 | --- | --- | --- | --- | --- | --- | 0 | --- | 25.6 | --- | --- | --- | --- | ---
Nilsen, 2009 | Catheter Aspiration | Control | 2917 | --- | --- | --- | --- | --- | --- | 0 | --- | 14.3 | --- | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^§^ | 990 | 63.3 (11.7) | 79.8 | 6.4 | 252 (288) | 13.9 | --- | 0 | 40.0 | --- | 31.3 | 53.0 | 47.2 | 66.0 | ---
Nakatani, 2007 | Catheter Aspiration | Control | 2923 | 64.9 (11.4) | 76.7 | 14.6 | 282 (330) | 13.6 | --- | 0 | 47.0 | --- | 34.2 | 53.8 | 43.5 | 66.5 | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | 239 | 62 (13) | 60 | --- | --- | 13 | 30.1 | 16 | 30.5 | --- | 15 | 49 | 56 | 47 | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | 1021 | 61 (13) | 50 | --- | --- | 11 | 49.8 | 15 | 50.2 | --- | 16 | 53 | 53 | 38 | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | 200 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | 1168 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

* Symptom onset to admission;

† Total study population;

‡ Mean for the total study population;

§ Multiple devices including Rescue catheter, Thrombuster catheter, Transvascular aspiration catheter and Export

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 34 Procedural characteristics of controlled observational studies

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Beaudoin, 2010 | Catheter Aspiration | Export | 165 | 41.2^*^ | --- | --- | 88 | 68% and 61% received clopidogrel loading dose of 600mg | ---
Beaudoin, 2010 | Catheter Aspiration | Control | 370 | 36.5 | --- | --- | 79 | | ---
Kim, 2010 | Thrombus Aspiration | Thrombus Aspiration | 429 | --- | --- | --- | 38.5 | 63.9% and 63.4% received clopidogrel loading dose of 600mg | ---
Kim, 2010 | Thrombus Aspiration | Control | 429 | --- | --- | --- | 38.5 | | ---
Ko, 2009 | Catheter Aspiration | Aspiration Catheter | --- | --- | --- | --- | --- | --- | ---
Ko, 2009 | Catheter Aspiration | Control | --- | --- | --- | --- | --- | --- | ---
Nilsen, 2009 | Distal Embolic Protection | Distal Protection Device | 381 | --- | --- | 155/381 (40.7) | --- | --- | ---
Nilsen, 2009 | Distal Embolic Protection | Control | 2917 | --- | --- | 855/2917(29.3) | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Multiple devices^*^ | 990 | --- | 784/990 (79.2) | --- | --- | --- | ---
Nakatani, 2007 | Catheter Aspiration | Control | 2923 | --- | 1789/2923 (61.2) | --- | --- | --- | ---
Chinnaiyan, 2006 | Mechanical Thrombectomy | AngioJet XMI or XVG Catheter | 239 | --- | 215/239 (90) | --- | 132/239 (55) | --- | Heparin (ACT>250 s)
Chinnaiyan, 2006 | Mechanical Thrombectomy | Control | 1021 | --- | 878/1021 (86) | --- | 639/1021 (63) | ---
Simonton, 2006 | Mechanical Thrombectomy | AngioJet | 200 | --- | --- | --- | --- | --- | ---
Simonton, 2006 | Mechanical Thrombectomy | Control | 1168 | --- | --- | --- | --- | --- | ---

* Multiple devices including Rescue catheter, Thrombuster catheter, Transvascular aspiration catheter and Export

Abbreviations: ACT=activated clotting time; GP2B3Ai=glycoprotein IIbIIIa inhibitor; n=number; N=number of participants in the group; s=seconds; SD=standard deviation

Table 35 Baseline characteristics of randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD)^*^ | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | 23 | 58 (10) | 82.61 | 34.78 | 186 (186) | 0 | --- | --- | 43 | --- | 61 | 48 | 65 | 74 | ---
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | 21 | 62 (8) | 80.95 | 90.48 | 126 (78) | 0 | --- | --- | 48 | --- | 19 | 52 | 90 | 81 | ---

* Symptom onset to arrival

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; MtPA=mutant plasminogen activator; N=number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 36 Procedural characteristics of randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Yamamoto, 2006 | Catheter Aspiration | Thrombuster+MtPA | 23 | 57 (22) | 23/23 (100) | --- | --- | Aspirin 100 mg and ticlopidine 100 mg pre-PCI and both for 6m post-PCI | Heparin 60 U/kg
Yamamoto, 2006 | Catheter Aspiration | Thrombuster | 21 | 64 (21) | 21/21 (100) | --- | ---

Abbreviations: ACT=activated clotting time; GP2B3Ai=glycoprotein IIbIIIa inhibitor; IU=International Units; kg=kilogram; m=months; mg=milligram; MtPA=mutant plasminogen activator; n=number; N=number of participants in the group; PCI=percutaneous coronary intervention; s=seconds; SD=standard deviation; U=units

Table 37 Baseline characteristics of randomized controlled trials with unique comparisons in patients with mixed acute coronary syndrome

Study, Year | Device Category | Group | N | Mean Age (SD) | Male (%) | TIMI-0/1 (%) | Mean Ischemic Time in Minutes (SD) | Prior MI (%) | Anterior MI (%) | Failed TL (%) | IRA LAD (%) | Visible Lesion (%) | DM (%) | HTN (%) | HCL (%) | Smoker (%) | FHx (%)
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | 57 | 57.75 (6.78) | 52.63 | 84.2 | 360 (240-540)^†^ | 22.81 | 43.86 | 0 | --- | 57.89 | 26.32 | 63.16 | 49.12 | 49.12 | ---
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | 63 | 58.71 (7.41) | 71.43 | 77.8 | 360 (300-720)^†^ | 20.63 | 41.27 | 0 | --- | 71.43 | 30.16 | 61.90 | 50.79 | 49.21 | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting + Distal Protection Device | 30 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---
Kanaya, 2003 | Thrombectomy + Distal Protection Device | Thrombectomy + Stenting | 30 | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | --- | ---

Abbreviations: DM=diabetes mellitus; FHx=family history; HCL=hypercholesterolemia; HTN=hypertension; IRA=infarct-related artery; LAD=left anterior descending artery; MI=myocardial infarction; N=total number of participants in the group; SD=standard deviation; TIMI=thrombolysis in myocardial infarction; TL=thrombolysis

Table 38 Procedural characteristics of randomized controlled trials with unique comparison in patients with mixed acute coronary syndrome

Study, Year | Device Category | Group | N | Mean Procedure Time in Minutes (SD) | Stenting n/N (%) | Direct Stenting n/N (%) | Procedural GP2B3Ai Use n/N (%) | Anti-platelet Drugs Used | Anti-thrombotic Drugs Used
Ochala, 2007 | Distal Balloon Embolic Protection | PercuSurge Guardwire | 57 | 58 (35-88)* | 57/57 (100) | 40/57 (57) | --- | Aspirin 300 mg and clopidogrel 300 mg pre-PCI | Device group: heparin 100 IU/kg (ACT >300 s)
Ochala, 2007 | Distal Balloon Embolic Protection | Abciximab | 63 | 43 (25-87)* | 63/63 (100) | 41/63 (65.7) | 63/63 (100) | | Abciximab group: heparin 70 IU/kg (ACT >250 s)
Kanaya, 2003 | Thrombectom y + Distal protection device | Thrombectomy + stenting + distal protection device | 30 | --- | 30/30 (100) | --- | --- | --- | ---
Kanaya, 2003 | Thrombectom y + Distal protection device | Thrombectomy + stenting | 30 | --- | 30/30 (100) | --- | --- | --- | ---

Abbreviations: GP2B3Ai=glycoprotein IIbIIIa inhibitor; n=number; N=number of participants in the group; SD=standard deviation