# Excluded Studies From Full-text Review

Reference | Reason for Exclusion
Adlbrecht C, Bonderman D, Plass C, et al. Thrombus bound endothelin and leukocytes extracted by thrombectomy in acute myocardial infarction correlate with ST-segment resolution [abstract]. Circulation 2006;114:458 | Uncontrolled study
Ai H, Wang CM, Zhu XL, et al. [Effect of aspiration of coronary thrombus upon prognosis of patients in primary percutaneous coronary intervention]. Chung-Hua i Hsueh Tsa Chih [Chinese Medical Journal] 2010;90:728-9 | Not an RCT or an observational study enrolling more than 500 patients
Ali A, Afzal A, Kazmouz G, et al. Rheolytic thrombectomy facilitates restoration of coronary flow in patients with acute myocardial infarction [abstract]. Am J Cardiol 2001;88:TCT63 | Not an RCT or an observational study enrolling more than 500 patients
Ali A, LaLond T, Schreiber T, et al. Reduction in no-flow, slow flow, and distal embolization with Angiojet thrombectomy-facilitated catheter-based reperfusion therapy for acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT268 | Not an RCT or an observational study enrolling more than 500 patients
Ali A., Malik FS, Collins T, et al. Reduction in QT dispersion with rheolytic thrombectomy in acute myocardial infarction: Evidence of electrical stability with reperfusion therapy [abstract]. Am J Cardiol 1997;80:TCT261 | Uncontrolled study
Ali A, Rehan A, Rahbar M, et al. Rheolytic thrombectomy in acute myocardial infarction results in a higher degree of ST-segment resolution [abstract]. Am J Cardiol 2002;90:TCT39 | Not an RCT or an observational study enrolling more than 500 patients
Ali A, Schreiber TL. The role of percutaneous thrombectomy in the contemporary treatment of acute myocardial infarction. J Invasive Cardiol 2004;16:546-8 | A narrative review, editorial or letter to the editor
Alidjan FMF, Koch KT, Henriques JP, et al. Combined embolic protection and thrombectomy in percutaneous coronary intervention of acute myocardial infarction using the Proxis (R) device [abstract]. Eur Heart J 2006;27:771 | Uncontrolled study
Alidjan F. Combined embolic protection and thrombectomy in percutaneous coronary intervention of acute myocardial infarction using the Proxis (R)-device [abstract]. Circulation 2006;114:739 | Uncontrolled study
Amabile N, Cochet A, Lorgis L, et al. Impact of thrombectomy devices for reperfusion of STEMI in the real world: insights from cardiac magnetic resonance imaging [abstract]. Circulation 2009;120:S337 | Not an RCT or an observational study enrolling more than 500 patients
Amato JL, Shamoon FE, Haft JI. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med 2008;358:2640 | A narrative review, editorial or letter to the editor
An Y, Kaji S, Yamamuro A, et al. Thrombus aspiration during primary percutaneous coronary intervention improves myocardial viability and infarct transmurality: a magnetic resonance imaging study [abstract]. J Am Coll Cardiol 2009;53:A282 | Not an RCT or an observational study enrolling more than 500 patients
Antoniucci D. Rheolytic thrombectomy in acute myocardial infarction: the Florence experience and objectives of the multicenter randomized JETSTENT trial. J Invasive Cardiol 2006;18:32C-34C | A narrative review, editorial or letter to the editor
Antoniucci D. Rheolytic thrombectomy in acute myocardial infarction: the Florence experience and objectives of the multicenter randomized JETSTENT trial. J Invasive Cardiol 2006;18:32C-34C | A narrative review, editorial or letter to the editor
Bartorelli AL. Acute thrombosis of a coronary artery aneurysm: toughing it out with the poor man's thrombectomy catheter technique. Catheter Cardiovasc Interv 2006;68:403-5 | A narrative review, editorial or letter to the editor
Bartorelli AL, Koh TH, Di Pede F, et al. The RUBY registry: assessment of distal embolic protection during coronary angioplasty in patients with acute coronary syndrome [abstract]. Circulation 2004;110:3403 | Uncontrolled study
Bass TA. Mechanical thrombectomy to the RESCUE. Catheter Cardiovasc Interv 2002;55:244 | A narrative review, editorial or letter to the editor
Bates ER. Aspirating and filtering atherothrombotic debris during percutaneous coronary intervention. JACC: Cardiovasc Interv 2008;1:265-7 | A narrative review, editorial or letter to the editor
Belardi J. Beyond the limit on percutaneous intervention of saphenous vein graft. Catheter Cardiovasc Interv 2005;64:387-8 | A narrative review, editorial or letter to the editor
Belli G, Silva P, Pezzano A, et al. Primary protected percutaneous intervention for acute myocardial infarction with the PercuSurge system in native coronary arteries [abstract]. Am J Cardiol 2000;86:79 | Uncontrolled study
Berger-Kucza A, Lelek M, Wita K, et al. Thrombus aspiration for microvascular protection in patients with acute MI undergoing early primary PCI [abstract]. Circulation 2008;118:E311 | Not an RCT or an observational study enrolling more than 500 patients
Bertrand OF, Larose E, Costerousse O, et al. Effects of Aspiration Thrombectomy on Necrosis Size and Ejection Fraction After Transradial Percutaneous Coronary Intervention in Acute St-Elevation Myocardial Infarction [abstract]. Can J Cardiol 2010; 26:106D | Not an RCT or an observational study enrolling more than 500 patients
Biasucci LM, de Maria GL, de Vito L, et al. Microparticles are increased in thrombectomy-aspirated blood of ST-elevation myocardial infarction patients and correlate with fibrinogen and thrombus burden [abstract]. J Thromb Haemost 2010;8:57 | Uncontrolled study
Bilge AK, Nisanci Y, Yilmaz E, et al. Effects of percutaneous coronary thrombectomy with the X-sizer catheter on epicardial flow and microvascular function in acute coronary syndrome. Clin Appl Thromb Hemost 2005;11:461-6 | Not an RCT or an observational study enrolling more than 500 patients
Blackman DJ, Channon KM. Prevention of embolisation during percutaneous vein graft intervention using a Filter Wire distal protection device. Heart 2003;89:376 | A narrative review, editorial or letter to the editor
Bonello L, De Labriolle A, Steinberg D, et al.Thrombus aspiration during percutaneous coronary intervention. Lancet 2008;372:1034 | A narrative review, editorial or letter to the editor
Buellesfeld L, Gerckens U, Grube E. [Background and indications for distal protection devices in percutaneous coronary interventions]. Dtsch Med Wochenschr 2006;131:2160-4 | A narrative review, editorial or letter to the editor
Burzotta F, Crea F. Thrombus-aspiration: a victory in the war against no reflow. Lancet 2008;371:1889-90 | A narrative review, editorial or letter to the editor
Burzotta F, Romagnoli E, Manzoli A, et al. The outcome of PCI for stent-ThrombosIs MultIcentre Study (OPTIMIST): rationale and design of a multicenter registry. Am Heart J 2007;153:377e1-e5 | Uncontrolled study
Carter AJ, Gregory K. Thrombo-atherectomy: hope for pesky thrombus-containing lesions? Catheter Cardiovasc Interv 2002;55:140-1 | A narrative review, editorial or letter to the editor
Carter LI, Golzar JA, Cavendish JJ, et al. Embolic protection of saphenous vein graft percutaneous interventions. J Interv Cardiol 2007;20:351-8 | A narrative review, editorial or letter to the editor
Chaliha BHK, Singh RS, Bahl A, et al. A study of abciximab versus distal protection device during percuteneous coronary stenting in acute coronary syndrome [abstract]. Indian Heart J 2004;56:417
Choi YS, Chung WS, Park CS, et al. Angiographic improvement after thrombus aspiration concomitant with glycoprotein IIb/IIIa inhibitor therapy does not affect long-term mortality during primary PCI [abstract]. Am J Cardiol 2009;103:AS8 | Not an RCT or an observational study enrolling more than 500 patients
Choudhury RP, Pillay P, Porto I, et al. Quantification of embolic material captured by the filterwire distal protection device during percutaneous intervention in native coronary arteries (NCA) and comparison with saphenous vein grafts (SVG) [abstract]. Heart 2004;90:51 | Uncontrolled study
Choudhury RP, Porto I, Banning AP. Images in cardiovascular medicine. Debris trapped by a distal protection device may mimic no-reflow during percutaneous coronary intervention. Circulation 2004;109:803-4 | Uncontrolled study
Chung WY, Cho YS, Chae IH, et al. The efficacy of distal protection device on ventricular remodeling and microvascular obstruction in ST elevation acute myocardial infarction [abstract]. Am J Cardiol 2006;98:M | Incomplete data and no response from author
Cohen DJ, Ramee S, Baim DS, et al. Economic assessment of rheolytic thrombectomy versus intracoronary urokinase for treatment of extensive intracoronary thrombus: Results from a randomized clinical trial. Am Heart J 2001;142:648-56 | Outside of ACS patients
Cohen R, Faucher R, Domniez T, et al. Predictive factors of successful intracoronary thrombectomy with the export aspiration catheter before angioplasty in patients with ST-segment elevation myocardial infarction [abstract]. Am Heart J 2006;98:59M | Not an RCT or an observational study enrolling more than 500 patients
Costa JR, Costa R, Feres F, et al. Preliminary experience with the Novel MGuard (TM) Stent System containing a protection net to prevent distal embolization - results from a prospective, non-randomized, single center study [abstract]. Circulation 2008;118:S745 | Uncontrolled study
Cox DA, Stuckey T, Babb J, et al. Early and late results of thrombectomy prior to stenting in acute myocardial infarction: Principal report of the EndiCOR X-SIZER AMI registry [abstract]. J Am Coll Cardiol 2002;39:308A | Uncontrolled study
Cox DA, Stuckey T, Babb J, et al. The EndiCOR X-SIZER AMI registry: Improvement in myocardial blush scores with adjunctive thrombectomy combined with stenting for AMI [abstract].Circulation 2001;104:2387 | Uncontrolled study
Cox DA, Stuckey T, Low R, et al. Adjunctive thrombectomy combined with stenting for AMI: The Endicor X-SIZER AMI registry [abstract]. J Am Coll Cardiol 2001;37:306S | Uncontrolled study
Cox DA, Turco M, Stuckey T, et al. Stent placement combined with thrombectomy improves outcomes in thrombotic lesions: Results from the X-SIZER acute myocardial infarction registry [abstract]. Am J Cardiol 2002;90:TCT124 | Uncontrolled study
Cox D, Lui H, Caputo R, et al. Lower MACE can be achieved in SVG PCI: Stenting in saphenous vein grafts with distal protection using a second generation filter-based catheter - The combined BLAZE I and BLAZE II registries [abstract]. Am J Cardiol 2005;96:5H | Uncontrolled study
Cox D, Stuckey T, Babb J, et al. The EndiCOR X-SIZER acute myocardial infarction (AMI) registry: Adjunctive thrombectomy combined with stenting for AMI [abstract]. Am J Cardiol 2001;88:TCT62 | Uncontrolled study
Cox D, Stuckey T, Babb J, et al. The X-SIZER acute myocardial infarction (AMI) registry: Improvement in myocardial blush scores and ST-segment resolution with the use of thrombectomy before stenting in AMI [abstract]. Am J Cardiol 2002;90:TCT38 | Uncontrolled study
Dangas,G. Interventional therapy for acute myocardial infarction: respect the microvasculature. J Am Coll Cardiol 2003;42:1403-5 | A narrative review, editorial or letter to the editor
De Carlo M, Cortese B, Borelli G, et al. Successful treatment of acute myocardial infarction due to subocclusive thrombosis over a small atherosclerotic plaque with the “Rinspiration” device, a novel thrombectomy catheter. Int J Cardiol 2007;115:95-6 | Uncontrolled study
De Carlo M, Webb JG, Grube E, et al. International Rinspiration Registry (100 patients treated with fluidic thrombectomy in the AMI setting) [abstract]. Am J Cardiol 2005; 96:76H-77H | Uncontrolled study
De Luca G, Suryapranata H, Chiariello M. Aspiration thrombectomy and primary percutaneous coronary intervention. Heart 2006;92:867-9 | A narrative review, editorial or letter to the editor
De Luca L, Sardella G. Tirofiban plus sirolimus-eluting stent vs abciximab plus bare-metal stent. JAMA 2005;294:1617 | A narrative review, editorial or letter to the editor
De Rosa S, Cirillo P, De Luca G, et al. Rheolytic thrombectomy during percutaneous coronary intervention improves long-term outcome in high-risk patients with acute myocardial infarction. J Interv Cardiol 2007;20:292-8 | Not an RCT or an observational study enrolling more than 500 patients
De Vita M, Burzotta F, Trani C, et al. Urgent PCI in patients with stent thrombosis: an observational single-center study comparing thrombus aspiration and standard PCI. J Invasive Cardiol 2008;20:161-5 | Uncontrolled study
De Young MB, Kazziha S. Use of a thrombus extraction catheter (Pronto) in the treatment of acute myocardial infarction after coronary embolism post mitral valve replacement. J Invasive Cardiol 2006;18:E273-5 | Uncontrolled study
DeLago A, Papaleo R, Macina A. Initial experience with Angiojet (R) mechanical thrombectomy in the treatment of acute myocardial infarction [abstract]. J Am Coll Cardiol 2000;35:19A | Uncontrolled study
Delgado A, Silva P, Klugmann S. Distal protection in native coronary arteries during primary angioplasty in acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT472 | Uncontrolled study
Dixon SR. Infarct angioplasty: beyond stents and glycoprotein IIb/IIIa inhibitors. Heart 2005;91:2-6 | A narrative review, editorial or letter to the editor
Dundon BK, Worthley MI, Worthley SG. Very late drug-eluting stent thrombosis. Heart Lung Circ 2008;17:144-5 | Uncontrolled study
Fabbiocchi F, Calligaris G, De Martini S, et al. Comparison between 2 different distal protection devices in acute myocardial infarction treated with percutaneous coronary intervention [abstract]. Am J Cardiol 2002;90:TCT492 | Uncontrolled study
Fabbiocchi F, Ravagnani P, Calligaris G. Combined distal protection and IIb/IIIa inhibitors vs distal protection alone during primary percutaneous coronary intervention in acute myocardial infarction: A randomized trial [abstract]. Am J Cardiol 2004;94:12E | Uncontrolled study
Fang HY, Hussein H, Hsueh SK, et al. Clinical Outcomes of the Routinely Used PercuSurge Device for High-Burden Thrombus Formation in the Infarct-Related Artery in Patients with ST-Segment Elevation Acute Myocardial Infarction: A Single-Center Experience [abstract]. Am J Cardiol 2010;105:34B | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Fiorentino RP, Zuckerman B, Uchida T. Regulatory perspective on embolic protection device approval for saphenous vein graft stenting with a single-arm trial using risk-adjusted prediction model. Circulation 2008;117:714-6 | A narrative review, editorial or letter to the editor
Fischell TA. Cleaning up the mess: new approaches to the old problem of thrombus in coronary interventions. J Invasive Cardiol 1999;11:485-7 | A narrative review, editorial or letter to the editor
Fischell TA, Subraya RG, Ashraf K, et al. Pharmacologic distal protection using prophylactic, intragraft nicardipine to prevent no-reflow and non-Q wave MI during SVG interventions [abstract]. Am J Cardiol 2005;96:124H | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Frobert O, Lagerqvist B, Gudnason T, et al. Thrombus Aspiration in ST-Elevation myocardial infarction in Scandinavia (TASTE trial). A multicenter, prospective, randomized, controlled clinical registry trial based on the Swedish angiography and angioplasty registry (SCAAR) platform. Study design and rationale.Am Heart J 2010 ;160:1042-48 | A narrative review, editorial or letter to the editor
Fortier S, Demaria RG, Pelletier GB, et al. Left ventricular thrombectomy in a cocaine user with normal coronary arteries. J Thorac Cardiovasc Surg 2003 ;125 :204-5 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Furuse Y, Muramatsu T, Tsukahara R, et al. Effectiveness of thrombectomy and distal protection for non-ST-segment elevation myocardial infarction [abstract]. Am J Cardiol 2005;95:6A-7A | Uncontrolled study
Galiuto L, Burzotta F, Garramone B, et al. Manual thrombus-aspiration reduces microvascular obstruction after PCI in unselected STEMI patients: MCE substudy of the randomised REMEDIA trial and insight into the pathogenesis of no-reflow [abstract]. Eur Heart J 2005;26:1962 | Does not report outcomes of interest
Galiuto L, Burzotta F, Garramone B, et al. Manual thrombus-aspiration reduces microvascular obstruction after PCI in unselected stemi patients: MCE substudy of the randomized REMEDIA trial [abstract]. Circulation 2005;112:3130 | Does not report outcomes of interest
Garcia E. Thrombus removal: clean the house before you settle. Catheter Cardiovasc Interv 2003;58:449-50 | A narrative review, editorial or letter to the editor
Garcia E, Alvarez A, Cubero JM, et al. Mid-term results of thrombus extraction in patients with ST elevation myocardial infarction: One center experience with the X-SIZER catheter system [abstract]. J Am Coll Cardiol 2003;41:356A | Uncontrolled study
Garcia E, Datino T, Pinto J, et al. Does thrombectomy with the X-sizer catheter system improve myocardial perfusion in patients with ST-segment elevation myocardial infarction? [abstract] Am J Cardiol 2006;97:53D | Not an RCT or an observational study enrolling more than 500 patients
Garcia E, Valdes M, Alvarez A, et al. Thrombectomy followed by elective stent implantation in ST elevation myocardial infarction. Results from the TASMI study [abstract]. Eur Heart J 2002;23:506 | Uncontrolled study
Gerckens U, Mueller R, Soblik S, et al. Prevention of distal embolization during interventions in CABG and native coronary lesions using a new protection filter device [abstract]. J Am Coll Cardiol 2000;35:10A-11A | Uncontrolled study
Gerckens U, Muller R, Rowold S, et al. The FilterWire (TM): First evaluation of a new protection catheter device for distal embolization in native coronary arteries and SVGs [abstract]. J Am Coll Cardiol 2001;37:34A-35A | Uncontrolled study
Ghahramani A. Rheolytic thrombectomy after suboptimal pharmacologic therapy for treatment of acute coronary syndrome. Am J Cardiol 2001;88:TCT181 | Uncontrolled study
Golebiewski S, Bartkowiak M, Pawlowski T, et al. [Successful thrombectomy with Diver aspirator in the treatment of acute myocardial infarct of the lower heart wall]. Kardiol Pol 2007;2:205-7 | Uncontrolled study
Gu YL, Fokkema ML, Zijlstra F. The emerging role of thrombus aspiration in the management of acute myocardial infarction. Circulation 2008;118:1780-2 | A narrative review, editorial or letter to the editor
Gu YL, van der Horst, Iwan C, et al. The role of coronary artery bypass grafting in ST-segment elevation myocardial infarction: a substudy from the thrombus aspiration during percutaneous coronary intervention in acute myocardial infarction study [abstract]. J Am Coll Cardiol 2009;53:A56 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Guang HW, Guo WT, Yun LJ, et al. The Efficiency and Safety of the Seek Aspiration Thrombectomy Catheter and Tirofiban in Primary Percutaneous Coronary Intervention of Acute Myocardial Infarction [abstract]. Heart 2010;96:e0482 | Does not report outcome of interest
Guigauri P, Dauerman HL. A novel use for a distal embolic protection device: stent retrieval. J Invasive Cardiol 2005;17:183-4 | Uncontrolled study
Haeck JD, Koch KT, Henriques JP, et al. One-year results of combined embolic protection and thrombectomy in percutaneous coronary intervention of acute myocardial infarction using the proxis (R)-device [abstract]. J Am Coll Cardiol 2007:49:32B | Uncontrolled study
Haery C, Exaire JE, Bhatt DL, et al. Use of PercuSurge GuardWire in native coronary arteries during acute myocardial infarction. J Invasive Cardiol 2004;16:152-4 | Uncontrolled study
Heuser RR. Embolic protection pas de deux. Catheter Cardiovasc Interv 2004;63:310 | A narrative review, editorial or letter to the editor
Hofmann R, Kypta A, Kerschner K, et al. Thrombus aspiration prior to primary angioplasty in acute myocardial infarction: estimation of rescued myocardial tissue by return of ST-segment elevation. Clin Cardiol 2004;27:451-4 | Not an RCT or an observational study enrolling more than 500 patients
Hong GR, Kang JH, Bae JH, et al. Effectiveness of distal protection device on the protection of microvascular integrity assessed by myocardial contrast echocardiography in patients with acute myocardial infarction [abstract]. Eur Heart J 2005;26:P2219 | Does not report outcome of interest
Horita Y, Kanaya H, Uno Y, et al. [Deterioration of cardiac function by combination therapy with mutant-tPA and guardwire plus for acute myocardial infarction: randomized study for acute myocardial infarction]. Japanese Journal of Interventional Cardiology;19:238-44 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Hui W, Sleik K, Cheung PK, et al. The benefit of filter wire distal protection for native vessel percutaneous coronary intervention in patients with acute coronary syndromes [abstract]. Am J Cardiol 2003;92:167L | Uncontrolled study
Ijiima R, Nakajima R, Tsunoda T, et al. Fate of unprotected side branches due to distal embolization during stent implantation for acute coronary syndromes using distal protection procedure [abstract]. Circulation 2004;110:3511 | Uncontrolled study
Inoue N, Fujita H, Matsuo A, et al. Efficacy of an aspiration device with distal protection for the treatment of acute myocardial infarction [abstract]. Am J Cardiol 2003;92:38L-39L | Not an RCT or an observational study enrolling more than 500 patients
Ito N, Morozumi T, Nanto S, et al. Myocardial salvage in acute myocardial infarction: Thrombectomy versus addition of a distal embolic protection device to primary angioplasty [abstract]. J Am Coll Cardiol 2005;45:268A | Not an RCT or an observational study enrolling more than 500 patients
Ito N, Nakamura M, Komatsu H, et al. Thrombectomy with distal protection prior to stenting is a novel strategy to obtain optimal reperfusion in patients with acute myocardial infarction [abstract]. J Am Coll Cardiol 2003;41:356A | Not an RCT or an observational study enrolling more than 500 patients
Ito N, Nakamura M, Nuruki H, et al. Thrombectomy prior to stenting is a novel strategy to obtain optimal reperfusion in acute myocardial infarction patients [abstract]. Eur Heart J 2002;23:269 | Not an RCT or an observational study enrolling more than 500 patients
Ito Y, Muramatsu T, Tsukahara R, et al. Dose thrombus aspiration with distal protection using PercuSurge (TM) before stenting for acute myocardial infarction reduce no-reflow phenomenon [abstract]? J Am Coll Cardiol 2004;43:285A | Incomplete data and no response from author
Ito Y, Muramatsu T, Tsukahara R, et al. Effectiveness of PercuSurge for acute myocardial infarction comparison with rescue catheter for clinical and pathological effectiveness [abstract]. Circulation 2003;107:55 | Not an RCT or an observational study enrolling more than 500 patients
Ito Y, Muramatsu T, Tsukahara R, et al. Effectiveness of the reperfusion therapy using a distal protection device guided by intravascular ultrasound for acute myocardial infarction [abstract]. Am J Cardiol 2006;97:8D | Incomplete data and no response from author
Ito Y, Muramatsu T, Tsukahara R, et al. Prevention of the no-reflow phenomenon and long-term prognosis of thrombus aspiration before stenting in acute myocardial infarction [abstract]. Eur Heart J 2004;25:420-1 | Not an RCT or an observational study enrolling more than 500 patients
Ito Y, Muramatsu T, Tsukahara R, et al. Efficacy of aspiration therapy under distal protection (PercuSurge) before stenting for acute myocardial infarction [abstract]. Am J Cardiol 2003;92:189L | Not an RCT or an observational study enrolling more than 500 patients
Ito Y, Muramatsu T, Tsukahara R, et al.Usefulness of reperfusion therapy with a distal protection device (percusurge) for acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT480 | Uncontrolled study
Ito Y, Muramatsu T, Tsukahara R, et al. Efficacy of suction thrombectomy for acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT487 | Uncontrolled study
Ito Y, Muramatsu T, Tsukahara R, et al. Success or lack of success of suction thrombectomy using the rescue catheter system in acute myocardial infarction and findings of intravascular ultrasound [abstract]. Am J Cardiol 2002;90:TCT488 | Not an RCT or an observational study enrolling more than 500 patients
Finkelstein A, Schwartzenberg S, Bar L, et al. Comparative efficacy analysis of an aspiration device before primary angioplasty in patients with acute myocardial infarction: a single-center experience. Isr Med Assoc J 2010;12:692-6 | Not an RCT or an observational study enrolling more than 500 patients
Jackson CE, Dalzell JR, Hogg KJ. Epinephrine treatment of anaphylaxis: an extraordinary case of very late acute stent thrombosis. Circulation 2009;2:79-81 | Uncontrolled study
Javaid A, Siddiqui NH, Buch AN, et al. Does thrombus aspiration improve angiographic and clinical outcomes for patients with ST elevation myocardial infarction undergoing primary percutaneous coronary intervention [abstract]? Circulation 2006;114:1759 | Not an RCT or an observational study enrolling more than 500 patients
Jeilan M, Richardson G, Gershlick A. Transvenous pacing causing tamponade in patients receiving glycoprotein IIb/IIIa inhibitors for percutaneous coronary intervention. J Invasive Cardiol 2007;19;E40-2 | Uncontrolled study
Kang WC, Ahn TH, Han SH, et al. Thrombosuction utilizing an export aspiration catheter during primary percutaneous coronary intervention in acute myocardial infarction. Yonsei Med J 2007;48:261-9 | Not an RCT or an observational study enrolling more than 500 patients
Kang,WC, Ahn TH, Han SH, et al. Efficacy of thrombosuction using the export aspiration catheter before or during primary percutaneous coronary intervention in acute myocardial infarction [abstract]. J Am Coll Cardiol 2005;45:86A | Not an RCT or an observational study enrolling more than 500 patients
Kang WC, Ahn TH, Han S, et al. Efficacy of thrombosuction using the export aspiration catheter before or during primary percutaneous coronary intervention in acute myocardial infarction [abstract]. Am J of Cardiol 2005;95:11A | Not an RCT or an observational study enrolling more than 500 patients
Kapoor N, Siddiqui T, Raza S, et al. Pharmacological distal protection using prophylactic intragraft adenosine prevent the slow-/no-reflow phenomenon. Am J of Cardiol 2008;102:1731-1741 | Not a PCI in native vessel
Kaul U. In search of an optimal reperfusion strategy following acute myocardial infarction. Indian Heart J 1997;49:549-50 | A narrative review, editorial or letter to the editor
Kawaguchi R, Hoshizaki H, Oshima S, et al. Does the rescue catheter improve treatment in patients with acute myocardial infarction? [abstract] Am J Cardiol 2003;92:113L | Not an RCT or an observational study enrolling more than 500 patients
Keeble W, Welsh R. A multifaceted approach to intracoronary thrombus: Use of pharmacology, an aspiration catheter and an embolic protection device. Can J Cardiol 2009;25:e391-2 | Uncontrolled study
Kelbaek H, Thuesen L, Helqvist S, et al. Drug-eluting versus bare metal stents in patients with ST-segment–elevation myocardial infarction eight-month follow-up in the drug elution and distal protection in acute myocardial infarction (DEDICATION) Trial. Circulation 2008;118:1155-62 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kelbaek H, Thuesen L, Helqvist S, et al. Drug-eluting versus bare metal stents in patients with ST-segment-elevation myocardial infarction: eight-month follow-up in the Drug Elution and Distal Protection in Acute Myocardial Infarction (DEDICATION) trial. Circulation 2008;118:1155-62 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Khosla S, Nemeth B. Percutaneous vascular rescue: A catheter-based approach to eliminate need for emergency vascular surgery after coronary and peripheral intervention [abstract]. Am J Cardiol 2001:88;TCT82 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kikuchi T, Sakurada M, Miyake T, et al. Effectiveness of reperfusion therapy using a TVAC thrombectomy catheter system for acute myocardial infarction [abstract]. Am J Cardiol 2004;94:153E | Not an RCT or an observational study enrolling more than 500 patients
Kikuchi T, Sakurada M, Miyake T, et al. Effectiveness of reperfusion therapy with a distal protection device (PercuSurge) for acute myocardial infarction [abstract]. Am J Cardiol 2003;92:191L-192L | Not an RCT or an observational study enrolling more than 500 patients
Kim JH, Kim BO, Kim KS, et al. Thrombus Aspiration in Primary Percutaneous Coronary Intervention Improves Early Myocardial Reperfusion in Patients with ST-Segment Elevation Myocardial Infarction without Upstream Use of Glycoprotein IIb/IIIa Inhibitors. Am J Cardiol 2010;105:4B | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kim BO, Kim JH, Cho SW, et al. A randomized controlled trial of upstream versus bail-out use of glycoprotein IIb/IIIa inhibitor combined with selective use of aspiration thrombectomy during primary percutaneous coronary intervention in patients with ST-segment elevation myocardial infarction [abstract]. Am J Cardiol 2009;104:117D-118D | Uncontrolled study
Kim BO, Lee BK, Goh CW, et al. Thrombus aspiration during primary percutaneous coronary intervention improves myocardial reperfusion with and without use of platelet glycoprotein IIb/IIIa receptor blockers [abstract]. Am J Cardiol 2009;103:AS98 | Uncontrolled study
Kini AS, Moreno PR, Mares AM, et al. The improved outcome with AngioJet(TM) thrombectomy catheter during primary stenting in acute myocardial infarction patients with high-grade thrombus [abstract]. Circulation 2006;114:507 | Not an RCT or an observational study enrolling more than 500 patients
Kira Y, Kosaka A, Ishihara Y, et al. [Myocardial infarction with normal coronary arteries]. Nippon Rinsho 2007;190:Suppl 5 Pt 2:190-3 | A narrative review, editorial or letter to the editor
Kirma C, Izgi A, Dundar C et al. Clinical and procedural predictors of no-reflow phenomenon after primary percutaneous coronary interventions: experience at a single center. Circulation 2008;72:716-21 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kishi T, Yamada A, Takemoto M, et al. Manual thrombectomy using a thrombuster catheter for acute myocardial infarction protects against left ventricular remodeling and congestive heart failure in cases involving the proximal left anterior descending and right coronary artery [abstract]. Am J Cardiol 2006;98:59M-60M | Not an RCT or an observational study enrolling more than 500 patients
Koch KT, De Winter RJ, Henriques JP, et al. Combined embolic protection and thrombectomy in percutaneous coronary intervention of acute myocardial infarction using the Proxis (R) device [abstract]. Am J Cardiol 2005;96:74H | Uncontrolled study
Koch K, DeWinter RJ, Henriques J, et al. Combined embolic protection and thrombectomy in percutaneous coronary intervention for acute myocardial infarction: Preliminary results using the proxis device [abstract]. Am J Cardiol 2004;2004:94:35E | Uncontrolled study
Koch KT, Kramer MCA, van der Wal AC, et al. Histopathological features of thrombectomy material obtained with proximal protection during primary PCI using the Proxis (R) device [abstract]. Am J Cardiol 2006;98:60M | Uncontrolled study
Koh TH. Proximal protection in SVG and stemi intervention [abstract]. Int J Cardiol 2007;122;25 | A narrative review, editorial or letter to the editor
Koller D, Schuiki E, Straumann E, et al. Advantages of aspiration thrombectomy before percutaneous catheter intervention in patients with acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT123 | Not an RCT or an observational study enrolling more than 500 patients
Komatsu H, Nakamura M, Ito N, et al. Primary angioplasty under distal protection is a useful strategy to obtain optimal myocardial reperfusion compared to the primary angioplasty with thrombectomy device in acute myocardial infarction patients [abstract]. J Am Coll Cardiol 2003;41:343A | Not an RCT or an observational study enrolling more than 500 patients
Koneru S, Pucillo A, Weiss MB, et al. Successful aspiration of occlusive coronary thrombus with intracoronary aspiration using the export catheter. J Invasive Cardiol 2003;15:65-7 | Uncontrolled study
Kosuga K, Tamai H. [Percutaneous coronary intervention: Current status of the development of new devices and the perspective of their future]. Nippon Rinsho 2003;61:529-33 | A narrative review, editorial or letter to the editor
Kramer MCA, van der Wal AC, Koch KT, et al. The efficacy of thrombus aspiration during primary PCI: evaluation of three eevices [abstract]. Am J Cardiol 2008;108:511 | Uncontrolled study
Kramer MC, van der Wal AC, Kock KT, et al. Histopathological features in primary PCI: a large single-center thrombectomy study [abstract]. J Am Coll Cardiol 2008;51:B79 | Uncontrolled study
Krstic N, Perisic Z, Pavlovic M, et al. Thrombus Aspiration during Primary Percutaneous Coronary Intervention. Circulation 2010;122:P782 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kuchela A, Sutsch G, Downey WE, et al. Embolic volume retrieved during native coronary percutaneous coronary intervention with distal protection is far lower than during saphenous vein graft percutaneous coronary intervention regardless of plaque burden [abstract]. J Am Coll Cardiol 2003;41:71A | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Kuehne C, Bollmann A, Husser D, et al. Thrombolytic therapy prior to coronary thrombectomy using the rescue PT catheter in acute myocardial infarction [abstract]. Eur Heart J 2002;23:723 | Uncontrolled study
Kuntz RE, Baim DS, Cohen DJ, et al. A trial comparing rheolytic thrombectomy with intracoronary urokinase for coronary and vein graft thrombus (the Vein Graft AngioJet Study [VeGAS 2]). Am J Cardiol 2002;89:326-30 | Outside of ACS patients
Kyono H, Kozuma K, Muramatsu T, et al. Angiographic impact of the GuardWire system on inflated coronary segments after six months: does the distal protection balloon of the GuardWire Plus lead to restenosis? Eurointervention 2010;6:257-260 | Not an RCT or an observational study enrolling more than 500 patients
Lansky AJ, Cox DA, Stuckey T, et al. Improved myocardial blush score after acute myocardial infarction intervention with the X-SIZER device. Results from the X-TRACT AMI trial [abstract]. Circulation 2001;104:2212 | Uncontrolled study
Larose E, Bertrand OF, Nguyen CM, et al. Reducing myocardial injury in late presentation acute ST-elevation myocardial infarction with proximal embolic protection [abstract]. Circulation 2009;120:S992 | Not an RCT or an observational study enrolling more than 500 patients
Lawson C, Garcia LA. Stent thrombosis aspiration thrombectomy: is this another glimmer of hope? J Invasive Cardiol 2009;21:214-5 | A narrative review, editorial or letter to the editor
Lee CH, Tan HC, Soon CY, et al. Does X-sizer thrombectomy abrogate the inferior outcomes in patients with impaired TIMI flow before mechanical reperfusion for acute myocardial infarction? Int J Cardiol 2005;103:212-3 | A narrative review, editorial or letter to the editor
Lee MS, Makkar R, Singh V, et al. Pre-procedural administration of aminophylline does not prevent AngioJet rheolytic thrombectomy-induced bradyarrhythmias. J Invasive Cardiol 2005;17:19-22 | Uncontrolled study
Lee SY, Doh JH, Namgung J, et al. Export aspiration catheter thrombosuction before actual primary angioplasty for acute myocardial infarction procedure [abstract]. Am J Cardiol 2005;95:29A | Uncontrolled study
Lemesle G, de Labriolle A, Bonello L, et al. Impact of thrombus aspiration use for the treatment of stent thrombosis on early patient outcomes. J Invasive Cardiol 2009;21:210-4 | Not an RCT or an observational study enrolling more than 500 patients
Li W, Xu Y, Wang K, et al. The Applying of Aspiration Catheter in Revascularisation in Patients with St-Elevation Myocardial Infarction. Heart 2010;96:e0419 | Uncontrolled study
Lim MJ. The AngioJet rheolytic thrombectomy system: does the end justify the means? J Invasive Cardiol 2005;17:23-24 | A narrative review, editorial or letter to the editor
Lim MJ, Young JJ, Senter SR, et al. Determinants of embolic protection device use: case study in the acceptance of a new medical technology. Catheter Cardiovasc Interv 2005;65:597-9 | Uncontrolled study
Limbruno U, Cortese B, Severi S. Thrombectomy for thrombus removal, filters for whatever else. J Cardiovasc Med 2008;9:408-9 | Uncontrolled study
Limbruno U, Micheli A, Petronio AS, et al. Prevention of no-reflow during primary percutaneous coronary angioplasty with a porous distal embolic protection device [abstract]. Circulation 2002;106:2220 | Not an RCT or an observational study enrolling more than 500 patients
Limbruno U, Michelli A, Petronio AS, et al. Adjunctive porous filter protection from distal embolization in primary percutaneous intervention for acute myocardial infarction [abstract]. J Am Coll Cardiol 2003; 41:46A | Not an RCT or an observational study enrolling more than 500 patients
Lucci D, Fabbri G, Maggioni AP. [The cardiologist and first aid: the situation in Italy]. G Ital Cardiol 1999;29:1-3 | A narrative review, editorial or letter to the editor
Maia S, Costa JR Jr, Costa RA, et al. Preliminary Experience with the Novel MGuard (TM) Stent System Containing a Protection Net to Prevent Distal Embolization - Results From a Prospective, Non-Randomized, Single Center Study [abstract]. Am J Cardiol 2008;102:1851 | Uncontrolled study
Maia F Sr, Costa JR Sr, Costa R Sr, et al. Acute results from the INSPIRE trial with the Novel MGuard (TM) Stent system containing a protection net to prevent distal embolization [abstract]. J Am Coll Cardiol 2009;53:A53 | Uncontrolled study
Mak KH, Phay C, Kwok V, et al. Distal protection device is superior to glycoprotein IIb/llla blockade in restoring myocardial perfusion during percutaneous coronary intervention for acute myocardial infarction [abstract]. Circulation 2003;108:3064 | Not an RCT or an observational study enrolling more than 500 patients
Mak KH, Phay C, Kwok V, et al. Superiority of the distal protection device over abciximab in preserving myocardial perfusion during percutaneous coronary intervention for acute myocardial infarction [abstract]. Am J Cardiol 2003;92:189L | Not an RCT or an observational study enrolling more than 500 patients
Mak KH, Phay C, Wong A, et al. Comparison between glycoprotein IIb/IIIa blockade and distal protection device for the restoration of myocardial perfusion during percutaneous coronary intervention for acute myocardial infarction. J Invasive Cardiol 2004;16:694-8 | Not an RCT or an observational study enrolling more than 500 patients
Mamas MA, Fraser D, Fath-Ordoubadi F. The role of thrombectomy and distal protection devices during percutaneous coronary interventions. Eurointervention 2008;4:115-23 | A narrative review, editorial or letter to the editor
Mangiacapra F;Muller O, Trana C, et al. Adjunctive thrombus aspiration in primary percutaneous coronary intervention in real-world patients with ST-elevation myocardial infarction [abstract]. Circulation 2009;120:S960 | Not an RCT or an observational study enrolling more than 500 patients
Mangiacapra F, Wijns W, De Luca G, et al. Thrombus aspiration in primary percutaneous coronary intervention in high-risk patients with ST-elevation myocardial infarction: a real-world registry. Catheter Cardiovasc Interv 2010;76:70-6 | Not an RCT or an observational study enrolling more than 500 patients
McClean D, Blake J, Richards M, et al. Distal protection with combination nonocclusive porous filter and aspiration thrombectomy improves ST segment resolution in primary percutaneous coronary intervention for acute myocardial infarction [abstract]. Am J Cardiol 2004; 94:34E | Not an RCT or an observational study enrolling more than 500 patients
Mehta S, Oliveros E, Ishmael A, et al. Selective strategy for thrombus management in STEMI interventions. J Invasive Cardiol 2010;22:26B-33B | Uncontrolled study
Michels RH, vanOmmen V, Heijmen EP, et al. Thrombectomy after failure of fibrinolytic drug therapy in acute myocardial infarction [abstract]. Circulation 1997;96:3620 | Uncontrolled study
Minocha G, Agarwal P, Chugh SK, et al. Primary thrombosuction with export aspiration catheter during percutaneous coronary intervention in acute coronary syndrome: Acute results and in-hospital outcomes [abstract]. J Am Coll Cardiol 2006;47:217A | Uncontrolled study
Mizote I, Kodama K, Hirayama A, et al. Distal protection device (PercuSurge) can reduce infarct size in patients with acute myocardial infarction who have ruptured culprit plaque [abstract]. J Am Coll Cardiol 2004;43:41A | Uncontrolled study
Mongeon FP, Eisenberg MJ, Rinfret S. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med 2008;358:2639-40 | A narrative review, editorial or letter to the editor
Morrison DA. Mechanical options to prevent distal embolization during primary percutaneous coronary intervention. Catheter Cardiovasc Interv 2009;74:94-6 | A narrative review, editorial or letter to the editor
Morrison DA‥ Is the glass 97% full, or 3% empty? Reinfarction and stent thrombosis after STEMI. Catheter Cardiovasc Interv 2009;73:635-6 | A narrative review, editorial or letter to the editor
Mukawa H, Sone T, Tsuboi H, et al. Reperfusion time-dependent myocardial salvage in patients with acute myocardial infarction who undergo emergent percutaneous coronary intervention with distal protection device PercuSurge [abstract]. J Am Coll Cardiol 2004;43:246A | Not an RCT or an observational study enrolling more than 500 patients
Murakami T, Mizuno S, Takahashi Y, et al. Intracoronary aspiration thrombectomy for acute myocardial infarction. Am J Cardiol 1998;82:839-44 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Nakagawa Y, Matsuo S, Tamura T, et al. AngioJet thrombectomy catheter for acute myocardial infarction [abstract]. J Am Coll Cardiol 1998;31:236A | Uncontrolled study
Nakamura T, Kubo N, Ikeda N, et al. Percutaneous coronary intervention with distal protection device preserves left ventricular function in patients with acute anterior myocardial infarction [abstract]. J Am Coll Cardiol 2004;43:246A | Not an RCT or an observational study enrolling more than 500 patients
Nakamura T, Kubo N, Seki Y, et al. Effects of a distal protection device during primary stenting in patients with acute anterior myocardial infarction. Circulation 2004;68:763-8 | Not an RCT or an observational study enrolling more than 500 patients
Nakazato R, Moroi M, Kunimasa T, et al. Usefulness of primary percutaneous coronary intervention with distal protection for acute myocardial infarction: assessment of salvaged myocardium with a rest [abstract]. Eur Heart J 2004;25:267 | Not an RCT or an observational study enrolling more than 500 patients
Nakazato R, Moroi M, Kunimasa T, et al. Usefulness of primary percutaneous coronary intervention with thrombectomy plus distal protection system for acute myocardial infarction: Assessment of salvaged myocardium with a rest thallium-201 and iodine-123 BMIPP SPECT [abstract]. J Am Coll Cardiol 2004;43:337A-338A | Not an RCT or an observational study enrolling more than 500 patients
Napodano M, Ramondo A, Iliceto S. Adjunctive thrombectomy in acute myocardial infarction: for some but not for all. J Am Coll Cardiol 2007;49:1586-7 | A narrative review, editorial or letter to the editor
Napodano M, Reimers B, Sacca S, et al. Mechanical intracoronary thrombus removal during acute myocardial infarction using the X-Sizer catheter [abstract]. Am J Cardiol 2000;86:249 | Uncontrolled study
Napodano M, Reimers B, Sacca S, et al. Coronary flow and myocardial reperfusion after thrombectomy during direct angioplasty in patients with acute myocardial infarction [abstract]. Eur Heart J 2001;22:119 | Uncontrolled study
Nassar Y, Elghawaby H, Elnaggar A, et al. X-SIZER thrombectomy compared to acolysis ultrasound thrombolysis in improving final epicardial flow and ST-segment resolution in patients with acute coronary syndromes [abstract]. Eur Heart J 2004;25:417-8 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Nishihira K, Yamashita A, Ishikawa T, et al. Composition of thrombi in late drug-eluting stent thrombosis versus de novo acute myocardial infarction. Thromb Res 2010;126:254-57 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Nishibori Y, Tanaka A, Nishiya D, et al. Intravascular ultrasound-guided percutaneous coronary intervention with distal protection device in acute myocardial infarction [abstract]. Am J Cardiol 2003;92:189L-190L | Not an RCT or an observational study enrolling more than 500 patients
Oh J, Hong N, Kang SM. Thrombus aspiration during percutaneous coronary intervention. Lancet 2008;372:1034-5 | A narrative review, editorial or letter to the editor
O'Neill WW. Coronary thrombosis during acute myocardial infarction: Roberts was right! Am J Cardiol 1998;82:896-7 | A narrative review, editorial or letter to the editor
Okamura A, Ito H, Iwakura K, et al. Detection of embolic particles with the Doppler guide wire during coronary intervention in patients with acute myocardial infarction: efficacy of distal protection device. J Am Coll Cardiol 2005;45:212-5 | Does not report outcomes of interest
Orrego PS, Delgado A, Piccalo G, et al. Distal protection in native coronary arteries during primary angioplasty in acute myocardial infarction: single-center experience. Catheter Cardiovasc Interv 2003;60:152-8 | Not an RCT or an observational study enrolling more than 500 patients
Oyama N, Urasawa K, Sakai H, et al. PCI for totally occluded site consisting of huge thrombus. J Invasive Cardiol 2003;15:604-6 | Uncontrolled study
Pan W, Wang LF, Yang SS, et al. [Efficacy of the thrombectomy on no-reflow in patients with acute myocardial infarction.] Zhongguo Wei Zhong Bing Ji Jiu Yi Xue 2007;19:687-90
Park CH, Salem M, Jauhar R, et al. Effect of distal protection or thrombectomy on corrected thrombolysis in myocardial infarction frame counts in stenting for acute myocardial infarction [abstract]. J Am Coll Cardiol 2003;41:356A-357A | Not an RCT or an observational study enrolling more than 500
Parodi G, Memisha G, Bellandi B, et al. Effectiveness of primary percutaneous coronary interventions for stent thrombosis. Am J Cardiol 2009;103:913-6 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Porto I, Choudhury RP, Pillay P, et al. Filter no-reflow during percutaneous coronary interventions using the filtewire distal protection device [abstract]. Eur Heart J 2004;25:312 | Uncontrolled study
Porto I, Greco F, Buffon A. Coronary arteriovenous fistula following X-sizer thrombectomy. J Cardiovasc Med 2007;8:973-4 | Uncontrolled study
Porto I, De Maria GL, Biasucci LM, et al. Levels of platelet microparticles are increased in thrombectomy-aspirated blood of ST-elevation myocardial infarction patients and correlate with thrombus burden of the culprit lesion [abstract]. Am J Cardiol 2009;104:76D | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Porto I, De Maria GL, Biasucci LM, et al. Levels of endothelial progenitor cells are increased in thrombectomy-aspirated blood of ST-elevation myocardial infarction patients and correlate with microvascular damage [abstract]. Am J Cardiol 2009;104:79D | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Porto L, Choudhury RP, Pillay P, et al. Filter no-reflow during percutaneous coronary intervention using the FilterWire distal protection device [abstract]. Am J Cardiol 2004;94:153E | Uncontrolled study
Reho I, Gruner C, Roffi M. Coronary thrombectomy by retrieval of an open emboli-protection filter device. Heart 2008;94:274 | Uncontrolled study
Remondino A, Seiler C, Rakhit R, et al. Distal embolisation protection during percutaneous coronary intervention in acute myocardial infarction protects coronary collateral flow [abstract]. Eur Heart J 2003;24:713 | Not an RCT or an observational study enrolling more than 500
Richartz BM. [Randomized comparison of the effect of distal protection and drug eluting stent versus bare metal stent implantation during percutaneous coronary intervention for ST-elevation myocardial infarction.] Herz 2007;32:249 | A narrative review, editorial or letter to the editor
Rigatelli G, Giordan M, Cardaioli P, et al. Peripheral devices for recanalizing a giant thrombosed aneurysmal coronary artery. Cardiovasc Revasc Med 2006;7:199-200 | Uncontrolled study
Rittersma SZ, van der Wal AC, Koch KT, et al. Plaque disruption frequently occurs days or weeks before occlusive coronary thrombosis: A pathologic thrombectomy study in primary PCI [abstract]. Circulation 2004;110:1941 | Uncontrolled study
Sakai T, Inoue S, Takei M, et al. Role of Inflammatory Cells Activation In Growing Thrombus: Immunohistochemical Analysis of Aspiration Samples in Acute Coronary Syndrome [abstract]. Circulation 2008;118:S581 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Sakuma T, Okada T, Hayashi Y, et al. Myocardial tissue protection with distal coronary protection and thrombus aspiration, or pharmacological intervention during reperfusion, which is better in patients with acute myocardial infarction? [abstract] Eur Heart J 2004;25:421 | Uncontrolled study
Sakuma T, Okada T, Ishibashi K, et al. Myocardial tissue protection with distal coronary protection and adenosine triphosphate disodium infusion can further reduce no-reflow in acute myocardial infarction [abstract]. J Am Coll Cardiol 2005;45:302A | Uncontrolled study
Sarmento-Leite R, Machado PR, Garcia,SL, et al. [Intracoronary thrombectomy. An alternative in the management of the acute ischemic syndromes.] Arq Bras Cardiol 2002;79:428 | Uncontrolled study
Satler L. Feasibility of primary clot extraction prior to percutaneous coronary intervention in acute myocardial infarction. Catheter Cardiovasc Interv 2008;71:877-8 | A narrative review, editorial or letter to the editor
Satler L. Improving outcomes for primary PCI. Catheter Cardiovasc Interv 2007;69:497-9 | A narrative review, editorial or letter to the editor
Satler L. Importance of creativity: new applications of the Proxis catheter. Catheter Cardiovasc Interv 2009;74:446-7 | A narrative review, editorial or letter to the editor
Schneider H, Ince H, Casale PN, et al. Efficacy And Safety Of A Thrombectomy Aspiration Device In Patients With High Thrombus Burden Acute Coronary Syndrome [abstract]. Am J Cardiol 2008;102:1201 | Uncontrolled study
Schomig A, Kastrati A. Distal embolic protection in patients with acute myocardial infarction: attractive concept but no evidence of benefit. JAMA 2005;293:1116-8 | A narrative review, editorial or letter to the editor
Sena MA., Peixoto RTS, Tedeschi AL. Thrombectomy with the X-Sizer catheter in thrombus-containing lesions during acute coronary syndrome. outcomes in-hospital and at 1year [abstract]. Am J Cardiol 2003;92:233L | Uncontrolled study
Seth A. Another “nail in the coffin” for protection devices in acute MI? Catheter Cardiovasc Interv 2008;71:E3-4 | A narrative review, editorial or letter to the editor
Shah PB, Lilly CM. Interventional therapy for coronary artery disease. Am J Respir Crit Care Med 2002;166:791-6 | A narrative review, editorial or letter to the editor
Sharma SK. Role of AngioJet rheolytic thrombectomy catheter: Mount Sinai Hospital experience. J Invasive Cardiol 2010;22:15B-20B | Not an RCT or an observational study enrolling more than 500
Sharma M, Yeghiazarians Y. Stent thrombosis--a complication best avoided. J Invasive Cardiol 2008;20:166-7 | A narrative review, editorial or letter to the editor
Sharma SK, Tamburrino F, Mares AM, et al. Improved outcome with AngioJet thrombectomy during primary stenting in acute myocardial infarction patients with high-grade thrombus. J Invasive Cardiol 2006;18:8-11 | Not an RCT or an observational study enrolling more than 500
Sheiban I, Moretti C, Prathap K, et al. Thrombus aspiration for the treatment of no-reflow phenomenon complicating primary angioplasty for acute myocardial infarction [abstract]. J Am Coll Cardiol 2004;43:248A | Uncontrolled study
Shiba M, Nakamura M, Wada M. The distal protection during primary PCI is associated with delayed recovery of myocardial perfusion in AMI patients [abstract]. Am J Cardiol 2005;95:28A-29A | Not an RCT or an observational study enrolling more than 500
Sievert H, Schuler G, Diederich K, et al. Preclinical and clinical experience with the proxis device: A novel proximal occlusion system for prevention of distal embolization during percutaneous coronary intervention [abstract]. Am J Cardiol 2002;90:TCT57 | Conducted outside of humans
Silva JA. Percutaneous coronary intervention of thrombotic lesions: still challenging! Catheter Cardiovasc Interv 2002;56:8-9 | A narrative review, editorial or letter to the editor
Silva JD, Seca L, Baptista R, et al. The role of thrombus aspiration in primary percutaneous coronary intervention: safety and efficacy [abstract]. Eur Heart J 2010; 12:F26 | Not an RCT or an observational study enrolling more than 500
Silva JA, Ramee SR, Cohen D, et al. Rheolytic thrombectomy for the treatment of acute myocardial infarction in patients with angiographic large thrombus burden: One-year results of the VeGAS 2 acute myocardial infarction registry [abstract]. J Am Coll Cardiol 2004;43:248A | Uncontrolled study
Silva JA, Ramee SR, Kuntz R, et al. Mechanical thrombectomy using the angiojet catheter in the treatment of acute myocardial infarction [abstract]. J Am Coll Cardiol 1998;31:410A-411A | Uncontrolled study
Silva JA., Saucedo JF, Lanoue AS, et al. Rheolytic thrombectomy using the POSSIS AngioJet -> catheter in patients with acute myocardial infarction presenting within eight hours of symptom onset [abstract]. Circulation 1998;98:762 | Uncontrolled study
Sison EOD, Tan HC, Lee R, et al. Thrombectomy using the thrombus vacuum catheter (Nipro (R)) in primary angioplasty for acute myocardial infarction [abstract]. Am J Cardiol 2005;96:75H-76H | Uncontrolled study
Skowasch M, Schofer J, Diedrich K, et al. Initial experiences with the Proxis System: A proximal occlusion device for embolic protection during percutaneous coronary intervention [abstract]. Am J Cardiol 2005;95:64A | Uncontrolled study
Stoel MG, von Birgelen C, Zijlstra F. Aspiration of embolized thrombus during primary percutaneous coronary intervention. Catheter Cardiovasc Interv 2009;73:781-6 | Uncontrolled study
Stone GW, Cox DA, Babb J, et al. Prospective, randomized evaluation of thrombectomy prior to percutaneous intervention in diseased saphenous vein grafts and thrombus-containing coronary arteries. J Am Coll Cardiol 2003;42:2007-13 | Outside of ACS patients
Stone, GW, Cox, DA, Low, R, et al. Safety and efficacy of a novel device for treatment of thrombotic and atherosclerotic lesions in native coronary arteries and saphenous vein grafts: results from the multicenter X-Sizer for treatment of thrombus and atherosclerosis in coronary applications trial (X-TRACT) study. Catheter Cardiovasc Interv 2003;58:419-27. | Not in native vessel
Sun Jiaan. No-Reflow Phenomenon in Primary PCI of AMI: Effect of Super-Selective Injection of Nitroprusside Combined with ZEEK Thrombus Aspiration. Circulation 2010;122:P1304 | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Sutsch G, Metzler C, Murphy S, et al. Distal protection accelerates ST-segment resolution and improves epicardial flow in percutaneous coronary intervention for acute myocardial infarction [abstract]. Am J Cardiol 2002;90:TCT43 | Uncontrolled study
Sutsch G, Eberli FR, Serruys PW. Evaluation of proximal embolic protection during percutaneous coronary intervention in acute myocardial infarction with Proxis.(TM) [abstract]. Am J Cardiol 2004;94:36E | Uncontrolled study
Sutsch G, Kiowski W, Amann W. The new reduced profile GuardWire (028) embolic protection device is feasible for percutaneous coronary intervention in native coronary arteries [abstract]. Am J Cardiol 2002;90:TCT90 | Uncontrolled study
Sutsch G, Kiowski W, Bossard A, et al. Recanalisation in acute myocardial infarction: preliminary experiences with the PercuSurge (R)-Protection device in native coronary arteries [abstract]. Eur Heart J 2000;21:P1003 | Uncontrolled study
Sutsch G, Murphy S, Kiowski W, et al. Does embolic protection in native coronary arteries acutely affect the outcome of percutaneous coronary intervention in acute myocardial infarction? [abstract] Am J Cardiol 2002;90:TCT110 | Not an RCT or an observational study enrolling more than 500
Sutsch G, Puippe G, Kessel M., et al. No angiographic evidence of harm, to native coronary arteries using the GuardWire distal embolization protection device [abstract]. Am J Cardiol 2001;88:TCT83 | Uncontrolled study
Szerlip M, Grines CL. The current role of AngioJet rheolytic thrombectomy in acute myocardial infarction. J Invasive Cardiol 2010;22:21B-22B | A narrative review, editorial or letter to the editor
Tamburrino F, Kini AS, Gupta S, et al. The improved outcome with AngioJet (TM) thrombectomy catheter during primary stenting in acute myocardial infarction patients with high-grade thrombus [abstract]. Am J Cardiol 2005;96:76H | Not an RCT or an observational study enrolling more than 500
Tarsia G;Polosa D, Biondi-Zoccai G, et al. Passive Versus Active Thrombectomy In Primary And Rescue Percutaneous Coronary Intervention For ST-elevation Acute Myocardial Infarction [abstract]. Am J Cardiol 2008;102:481 | Not an RCT or an observational study enrolling more than 500
Testa L, Bedogni F, Biondi Zoccai GG. Letter by Testa et al regarding article, “presence of older thrombus is an independent predictor of long-term mortality in patients with ST-elevation myocardial infarction treated with thrombus aspiration during primary percutaneous coronary intervention”. Circulation 2009;120:e3 | A narrative review, editorial or letter to the editor
Tomoda H, Izumi N, Aoki N. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med 2008;358:2540 | A narrative review, editorial or letter to the editor
Tsubotan T, Muramatsu T, Tsukahara R, et al. Clinical results of intravascular ultrasound-guided distal protection therapy for acute myocardial infarction [abstract]. Am J Cardiol 2005;95:9A | Not an RCT or an observational study enrolling more than 500
Turco MA, Cox DA, Stuckey T, et al. Impact of glycoprotein IIb/IIIa inhibitors in conjunction with the X-SIZER thrombectomy catheter system during acute myocardial infarction (AMI) intervention: Results from the X-SIZER AMI registry [abstract]. Am J Cardiol 2002;90:TCT121 | Uncontrolled study
Upadhyay S, Sawar A. Device failure and acute vessel thrombosis with PercuSurge. J Invasive Cardiol 2008;20:E256 | Uncontrolled study
Uretsky BF. Thrombus aspiration during primary percutaneous coronary intervention. N Engl J Med 2008;358:2639 | A narrative review, editorial or letter to the editor
van Ommen V, Michels R, Heymen E, van Asseldonk J, et al. Usefulness of the rescue PT catheter to remove fresh thrombus from coronary arteries and bypass grafts in acute myocardial infarction. Am J Cardiol 2001;88:306-8 | Uncontrolled study
Vink MA, Dirksen MT, Tijsserr JGP, et al. Thrombus Aspiration During Primary Percutaneous Coronary Intervention: Post-hoc Analysis of the PASSION Trial [abstract]. Am J Cardiol 2009;104:197D | Uncontrolled study
Vink MA., Patterson MS, Van Etten J, et al. Thrombus Removal by Extraction or Aspiration in Primary PCI in the Treatment of ST-elevation Myocardial Infarction (TREAT-MI). A follow-up study [abstract]‥ Am J Cardiol 2009;104:197D-198D | Uncontrolled study
Vlaar PJ, Diercks G, Svilaas T, et al. One-year follow-up of the Thrombus Aspiration during Primary percutaneous coronary intervention in Acute non-ST-elevation myocardial infarction Study (TAPAS-II) - pilot – trial [abstract]. J Am Coll Cardiol 2009;53:A64 | Not an RCT or an observational study enrolling more than 500
von Korn H, Yu JT, Ohlow M, et al. The export aspiration system in patients with acute coronary syndrome and visible thrombus demonstrates no remarkable benefit [abstract]. J Am Coll Cardiol 2006;47:38B | Not an RCT or an observational study enrolling more than 500
Wang FW, Osman A, Otero J, et al. Distal myocardial protection with intracoronary propranolol during percutaneous coronary intervention is widely applicable [abstract]. J Am Coll Cardiol 2003;41:17A | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Wang L, Nguyen T, Yang X, et al. Distal protection with AngioGuard during PCI for acute myocardial infarction [abstract]. Am J Cardiol 2003;92:38L | Not an RCT or an observational study enrolling more than 500
Weisz G, Rogers C, Herrmiller J, et al. Predilatation before distal protection device placement is associated with increased procedure-related myocardial infarction: Analysis from the FIRE trial [abstract]. J Am Coll Cardiol 2004;43:52A | Not a PCI in native vessel
Wong A, Nait D, Phay C, et al. Rate of distal embolization in primary angioplasty in acute myocardial infarction without distal embolization prevention and thrombectomy devices [abstract]. Am J Cardiol 2005;95:12A | Not evaluating an adjunctive device to remove thrombus and/or protect from distal embolization prior to or in PCI
Worthley MI, Traboulsi M. Thrombectomy and acute myocardial infarction. Intern Med J 2006;36:470-1 | Uncontrolled study
Yamaguchi K, Hiasa Y, Nada T, et al. Rescue percutaneous thrombectomy catheter is less beneficial in acute myocardial infarction with large vessel diameter [abstract]. Eur Heart J 2002;23:350 | Uncontrolled study
Yamasaki T, Koizumi T, Iida S, et al. Benefit of thrombus aspiration for myocardial infarction with ST-segment elevation: analysis by biomarkers of thrombosis and inflammation [abstract]. Circulation 2009;120:S926 | Uncontrolled study
Yang SS, Li WM, Zhou LJ, et al. [The efficacy of percutaneous coronary intervention combined percutaneous thrombectomy on coronary thrombotic lesions in patients with acute myocardial infarction]. Zhonghua Xin Xue Guan Bing Za Zhi 2007;35:1136-40 | Does not report outcomes of interest
Yip HK, Wu CJ, Chang HW, et al. Effect of the PercuSurge GuardWire device on the integrity of microvasculature and clinical outcomes during primary transradial coronary intervention in acute myocardial infarction. Am J Cardiol 2003;92:1331-5 | Not an RCT or an observational study enrolling more than 500
Yoon MH, Tahk SJ, Choi SY, et al. The effect of distal protection device on the protection of microvascular integrity during primary stenting in AMI [abstract]. Circulation 2003;108:1877 | Not an RCT or an observational study enrolling more than 500
Yoon MH, Tahk SJ, Choi SY, et al. The effect of a distal protection device on the protection of microvascular integrity during primary stenting in acute myocardial infarction [abstract]. Am J Cardiol 2003;92:37L | Not an RCT or an observational study enrolling more than 500
Yoshida K, Oku K, Uchida Y, et al. The effect for chronic phase left ventricular ejection fraction using adjunctive distal protection during percutaneous coronary intervention in patients with acute coronary syndrome [abstract]. Am J Cardiol 2005;95:28A | Not an RCT or an observational study enrolling more than 500
Zalewski D, Zajdel W, El-Massri N, et al. The immediate and long-term results of successful thrombectomy during primary coronary angioplasty in acute myocardial infarction [abstract]. Am J Cardiol 2005;96:74H | Uncontrolled study