# Characteristics and Quality Assessment of Included Trials, Studies and Systematic Reviews With Meta-analyses

Table 1 Characteristics and quality assessment of randomized controlled trials evaluating catheter aspiration devices versus control in patients with ST-segment elevation myocardial infarction

Table 2 Characteristics and quality assessment of randomized controlled trials evaluating mechanical thrombectomy devices versus control in patients with ST-segment elevation myocardial infarction

Table 3 Characteristics and quality assessment of randomized controlled trials evaluating distal filter embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Table 4 Characteristics and quality assessment of randomized controlled trials evaluating distal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Table 5 Characteristics and quality assessment of randomized controlled trials evaluating proximal balloon embolic protection devices versus control in patients with ST-segment elevation myocardial infarction

Table 6 Characteristics and quality assessment of randomized controlled trials evaluating thrombectomy or distal protection devices versus control in patients with unstable angina or non-ST-segment elevation myocardial infarction

Table 7 Characteristics and quality assessment of randomized controlled trials evaluating thrombectomy or distal protection devices versus control in the mixed acute coronary syndrome population

Table 8 Characteristics and quality assessment of direct comparative randomized controlled trials in patients with ST-segment elevation myocardial infarction

Table 9 Characteristics and quality assessment of randomized controlled trials with selective inclusion/exclusion criteria in patients with ST-segment elevation myocardial infarction

Table 10 Characteristics and quality assessment of randomized controlled trials with unique comparisons in patients with ST-segment elevation myocardial infarction

Table 11 Characteristics and quality assessment of randomized controlled trials with unique comparisons in patients with mixed acute coronary syndrome

Table 12 Characteristics and quality assessment of controlled observational studies

Table 13 Characteristics and quality assessment of systematic reviews with meta-analysis published as full text

Table 14 Characteristics and quality assessment of systematic reviews with meta-analyses published in abstract form