# Appendixes

Appendix A Exact Search Strategy

Appendix B Data Extraction Form

Appendix C Characteristics and Quality Assessment of Included Trials, Studies and Systematic Reviews With Meta-analyses

Appendix D Excluded Studies From Full-text Review

Appendix E Baseline and Procedural Characteristics of Included Trials and Studies

Appendix F Additional Evidence Tables and Reference List

Appendix G Strength of Evidence for Outcomes

Appendix H Applicability of Individual Studies and of the Body of Evidence

Appendix I Forest Plots for Results of Final Health Outcomes Analyzed at Individual Time Points

Appendix J Glossary