# Acronyms/Abbreviations

Acronym/Abbreviation: Definition
ACC: American College of Cardiology
ACS: Acute coronary syndrome
ACT: Activated clotting time
AHRQ: Agency for Healthcare Research and Quality
AMI: Acute myocardial infarction
CAD: Coronary artery disease
CABG: Coronary artery bypass graft
CER: Comparative effectiveness review
CHF: Congestive heart failure
CI: Confidence interval
cm: centimeters
Cr: Creatinine
cTFC: Corrected TIMI frame count
Cx: Circumflex coronary artery
D: Days
DE: Distal embolization
ECG: Electrocardiogram
ECHO: Echocardiogram
EF: Ejection fraction
EPC: Evidence-based Practice Center
FHx: Family history
GI: Gastrointestinal
GP2B3Ai: Glycoprotein 2b3a inhibitor
GRADE: Grading of Recommendations Assessment, Development and Evaluation
H: Hours
HCL: Hypercholesterolemia
HD: Hemodialysis
HTN: Hypertension
IABP: Intra-aortic balloon pump
IRA: Infarct related artery
IU: International units
IV: Intravenous
IVUS: Intravascular ultrasound
Kg: Kilograms
LAD: Left anterior descending artery
LBBB: Left bundle branch block
LCX: Left circumflex
LV: Left ventricle
LVEF: Left ventricular ejection fraction
M: Month
MACE: Major adverse cardiovascular event
MACCE: Major adverse cerebrovascular and cardiovascular event
MBG: Myocardial blush grade
Mg/dL: Milligrams per deciliter
MI: Myocardial infarction
Min: Minutes
mm: Millimeters
MRI: Magnetic resonance imaging
MtPA: Mutant TPA
mV: milivolts
NR: Not reported
NSTEMI: NonST-segment elevation myocardial infarction
PCI: Percutaneous coronary intervention
PO: By mouth
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
RCA: Right coronary artery
RCT: Randomized controlled trials
RD: Risk difference
RR: Relative risk
S: Seconds
SCr: Serum creatinine
SPECT: Single-photon emission computerized tomography
STEMI: ST-segment elevation myocardial infarction
STSR: ST-segment resolution
SVG: Saphenous vein graft
TEP: Technical Expert Panel
TBG: TIMI blush grade
TIMI: Thrombolysis in myocardial infarction
TMPG: TIMI myocardial perfusion grade
TL: Thrombolysis
TLR: Target lesion revascularization
TS: Thrombus score
TVAC^®^: Transvascular aspiration catheter
TVR: Target vessel revascularization
U: Units
UA: Unstable angina
Y: Years