# Acknowledgments

The authors gratefully acknowledge Nancy White, who provided assistance with editing and project management.