# Technical Expert Panel

Sawsan As-Sanie, M.D., M.P.H.

Director, Chronic Pelvic Pain Program and Minimally Invasive Surgery Fellowship

University of Michigan

Ann Arbor, MI

Esther Eisenberg, M.D., M.P.H.

Project Scientist, Reproductive Medicine Network, National Institute of Child Health and Development

Department of Obstetrics and Gynecology, Vanderbilt Medical Center

Nashville, TN

Bruce Lessey, M.D., Ph.D.

Vice Chair, Research

Center for Women’s Medicine, Greenville Hospital System

Greenville, SC

Steve Phurrough, M.D., M.P.A.

Chief Operating Officer and Senior Clinical Director, Center for Medical Technology and Policy

Baltimore, MD

Frank Tu, M.D., M.P.H.

Director, Division of Gynecological Pain and Minimally Invasive Surgery

NorthShore University Health System

Chicago, IL