# References

1 ACOG Practice Bulletin No. 51. Chronic pelvic pain. Obstet Gynecol. Mar. 2004;103(3):589-605. [pmid: 14990428].
2 Stones W, Cheong Ying C, Howard Fred M, et al. Interventions for treating chronic pelvic pain in women. Cochrane Database of Systematic Reviews. 2005.
3 Leserman J, Zolnoun D, Meltzer-Brody S, et al. Identification of diagnostic subtypes of chronic pelvic pain and how subtypes differ in health status and trauma history. Am J Obstet Gynecol. Aug. 2006;195(2):554-60. discussion 560-1. [pmid: 16769027].
4 Howard FM. The role of laparoscopy in chronic pelvic pain: promise and pitfalls. Obstet Gynecol Surv. Jun. 1993;48(6):357-87. [pmid: 8327235].
5 Howard FM. Chronic pelvic pain. Obstet Gynecol. Mar. 2003;101(3):594-611. [pmid: 12636968].
6 Reiter RC. Evidence-based management of chronic pelvic pain. Clin Obstet Gynecol. Jun. 1998;41(2):422-35. [pmid: 9646974].
7 Latthe P, Mignini L, Gray R, et al. Factors predisposing women to chronic pelvic pain: systematic review. BMJ: British Medical Journal. Apr. 2006;332(7544):749-755.
8 Zondervan KT, Yudkin PL, Vessey MP, et al. Prevalence and incidence of chronic pelvic pain in primary care: evidence from a national general practice database. Br J Obstet Gynaecol. Nov. 1999;106(11):1149-55. [pmid: 10549959].
9 Reiter RC. A profile of women with chronic pelvic pain. Clinical Obstetrics and Gynecology. 1990;33(1):130-136. [pmid: 2178830].
10 Mathias SD, Kuppermann M, Liberman RF, et al. Chronic pelvic pain: prevalence, health-related quality of life, and economic correlates. Obstet Gynecol. Mar. 1996;87(3):321-7. [pmid: 8598948].
11 Stanford EJ, Dell JR, Parsons CL. The Emerging Presence of Interstitial Cystitis in Gynecologic Patients with Chronic Pelvic Pain. Urology. 2007;69(4 SUPPL):S53-S59.
12 Zondervan KT, Yudkin PL, Vessey MP, et al. The community prevalence of chronic pelvic pain in women and associated illness behaviour. Br J Gen Pract. Jul. 2001;51(468):541-7. [pmid: 11462313].
13 Zondervan KT, Yudkin PL, Vessey MP, et al. Chronic pelvic pain in the community--symptoms, investigations, and diagnoses. Am J Obstet Gynecol. May. 2001;184(6):1149-55. [pmid: 11349181].
14 Grace V, Zondervan K. Chronic pelvic pain in women in New Zealand: comparative well-being, comorbidity, and impact on work and other activities. Health Care Women Int. Aug. 2006;27(7):585-99. [pmid: 16844672].
15 Grace VM, Zondervan KT. Chronic pelvic pain in New Zealand: prevalence, pain severity, diagnoses and use of the health services. Aust N Z J Public Health. Aug. 2004;28(4):369-75. [pmid: 15704703].
16 Steege JF, Stout AL. Resolution of chronic pelvic pain after laparoscopic lysis of adhesions. Am J Obstet Gynecol. Aug. 1991;165(2):278-81. discussion 281-3. [pmid: 1831321].
17 Reiter RC, Gambone JC. Nongynecologic somatic pathology in women with chronic pelvic pain and negative laparoscopy. J Reprod Med. Apr. 1991;36(4):253-9. [pmid: 1830102].
18 Cheong Y, William Stones R. Chronic pelvic pain: aetiology and therapy. Best Pract Res Clin Obstet Gynaecol. Oct. 2006;20(5):695-711. [pmid: 16765092].
19 Clemons JL, Arya LA, Myers DL. Diagnosing interstitial cystitis in women with chronic pelvic pain. Obstet Gynecol. Aug. 2002;100(2):337-41. [pmid: 12151160].
20 Hammoud A, Gago LA, Diamond MP, et al. Adhesions in patients with chronic pelvic pain: a role for adhesiolysis?. Fertil Steril. Dec. 2004;82(6):1483-91. [pmid: 15589847].
21 Jarrell JF, Vilos GA, Allaire C, et al. Consensus guidelines for the management of chronic pelvic pain. J Obstet Gynaecol Can. Aug. 2005;27(8):781-826. [pmid: 16287011].
22 Kontoravdis A, Chryssikopoulos A, Hassiakos D, et al. The diagnostic value of laparoscopy in 2365 patients with acute and chronic pelvic pain. Int J Gynaecol Obstet. Mar. 1996;52(3):243-8. [pmid: 8775676].
23 Prior A, Whorwell PJ. Gynaecological consultation in patients with the irritable bowel syndrome. Gut. Jul. 1989;30(7):996-8. [pmid: 2759494].
24 Stovall TG, Elder RF, Ling FW. Predictors of pelvic adhesions. J Reprod Med. May. 1989;34(5):345-8. [pmid: 2525188].
25 Trimbos JB, Trimbos-Kemper GC, Peters AA, et al. Findings in 200 consecutive asymptomatic women, having a laparoscopic sterilization. Arch Gynecol Obstet. 1990;247(3):121-4. [pmid: 2142404].
26 van Os-Bossagh P, Pols T, Hop WC, et al. Voiding symptoms in chronic pelvic pain (CPP). Eur J Obstet Gynecol Reprod Biol. Apr. 25. 2003;107(2):185-90. [pmid: 12648866].
27 Hanno PM, Burks DA, Clemens JQ, et al. AUA guideline for the diagnosis and treatment of interstitial cystitis/bladder pain syndrome. J Urol. Jun. 2011;185(6):2162-70. [pmid: 21497847].
28 Giamberardino MA, Costantini R, Affaitati G, et al. Viscero-visceral hyperalgesia: characterization in different clinical models. Pain. Nov. 2010;151(2):307-22. [pmid: 20638177].
29 Longstreth GF, Preskill DB, Youkeles L. Irritable bowel syndrome in women having diagnostic laparoscopy or hysterectomy. Relation to gynecologic features and outcome. Dig Dis Sci. Oct. 1990;35(10):1285-90. [pmid: 2145139].
30 Walker EA, Gelfand AN, Gelfand MD, et al. Chronic pelvic pain and gynecological symptoms in women with irritable bowel syndrome. J Psychosom Obstet Gynaecol. Mar. 1996;17(1):39-46. [pmid: 8860885].
31 Riedl A, Schmidtmann M, Stengel A, et al. Somatic comorbidities of irritable bowel syndrome: A systematic analysis. Journal of Psychosomatic Research. Jun. 2008;64(6):573-582. [pmid: 18501257].
32 Chung MK. Interstitial cystitis in persistent posthysterectomy chronic pelvic pain. JSLS. Oct-Dec. 2004;8(4):329-33. [pmid: 15554275].
33 Treatment of pelvic pain associated with endometriosis. Fertil Steril. Nov. 2006;86(5 Suppl 1):S18-27.
34 Guo SW, Wang Y. The prevalence of endometriosis in women with chronic pelvic pain. Gynecol Obstet Invest. 2006;62(3):121-30. [pmid: 16675908].
35 Walker EA, Katon WJ, Hansom J, et al. Psychiatric diagnoses and sexual victimization in women with chronic pelvic pain. Psychosomatics. Nov-Dec. 1995;36(6):531-40. [pmid: 7501783].
36 McGowan LPA, Clark-Carter DD, Pitts MK. Chronic pelvic pain: A meta-analytic review. Psychology & Health. Oct. 1998;13(5):937-951.
37 Meltzer-Brody S, Leserman J, Zolnoun D, et al. Trauma and posttraumatic stress disorder in women with chronic pelvic pain. Obstet Gynecol. Apr. 2007;109(4):902-8. [pmid: 17400852].
38 Jamieson DJ, Steege JF. The association of sexual abuse with pelvic pain complaints in a primary care population. Am J Obstet Gynecol. Dec. 1997;177(6):1408-12. [pmid: 9423743].
39 Walling MK, O'Hara MW, Reiter RC, et al. Abuse history and chronic pain in women: II. A multivariate analysis of abuse and psychological morbidity. Obstet Gynecol. Aug. 1994;84(2):200-6. [pmid: 8041530].
40 Walling MK, Reiter RC, O'Hara MW, et al. Abuse history and chronic pain in women: I. Prevalences of sexual abuse and physical abuse. Obstet Gynecol. Aug. 1994;84(2):193-9. [pmid: 8041529].
41 Collett BJ, Cordle CJ, Stewart CR, et al. A comparative study of women with chronic pelvic pain, chronic nonpelvic pain and those with no history of pain attending general practitioners. Br J Obstet Gynaecol. Jan. 1998;105(1):87-92. [pmid: 9442168].
42 Lampe A, Doering S, Rumpold G, et al. Chronic pain syndromes and their relation to childhood abuse and stressful life events. J Psychosom Res. Apr. 2003;54(4):361-7. [pmid: 12670615].
43 Lampe A, Solder E, Ennemoser A, et al. Chronic pelvic pain and previous sexual abuse. Obstet Gynecol. Dec. 2000;96(6):929-33. [pmid: 11084180].
44 Toomey TC, Seville JL, Mann JD, et al. Relationship of sexual and physical abuse to pain description, coping, psychological distress, and health-care utilization in a chronic pain sample. Clin J Pain. Dec. 1995;11(4):307-15. [pmid: 8788578].
45 Zondervan KT, Yudkin PL, Vessey MP, et al. Patterns of diagnosis and referral in women consulting for chronic pelvic pain in UK primary care. Br J Obstet Gynaecol. Nov. 1999;106(11):1156-61. [pmid: 10549960].
46 Howard FM. Treatment of chronic pelvic pain in women. UpToDate. 2010.
47 Howard FM. Evaluation of chronic pelvic pain in women. UpToDate. 2011.
48 International Pelvic Pain Society. History and physical form. 2002. Available at: http://www.pelvicpain.org/resources/handpform.aspx.
49 Engel GL. The need for a new medical model: a challenge for biomedicine. Science. Apr. 8. 1977;196(4286):129-36. [pmid: 847460].
50 Howard FM, El-Minawi AM, Sanchez RA. Conscious pain mapping by laparoscopy in women with chronic pelvic pain. Obstet Gynecol. Dec. 2000;96(6):934-9. [pmid: 11084181].
51 Daniels J, Gray R, Hills RK, et al. Laparoscopic uterosacral nerve ablation for alleviating chronic pelvic pain: a randomized controlled trial. JAMA. Sep. 2. 2009;302(9):955-61. [pmid: 19724042].
52 Winkel CA. Role of a symptom-based algorithmic approach to chronic pelvic pain. Int J Gynaecol Obstet. Sep. 2001;74(Suppl 1):S15-20. [pmid: 11549395].
53 Price J, Farmer G, Harris J, et al. Attitudes of women with chronic pelvic pain to the gynaecological consultation: a qualitative study. BJOG. Apr. 2006;113(4):446-52. [pmid: 16489938].
54 Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women's Health Study: II. Outcomes of nonsurgical management of leiomyomas, abnormal bleeding, and chronic pelvic pain. Obstet Gynecol. Apr. 1994;83(4):566-72. [pmid: 8134067].
55 Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women's Health Study: I. Outcomes of hysterectomy. Obstet Gynecol. Apr. 1994;83(4):556-65. [pmid: 8134066].
56 Stovall TG, Ling FW, Crawford DA. Hysterectomy for chronic pelvic pain of presumed uterine etiology. Obstet Gynecol. Apr. 1990;75(4):676-9. [pmid: 2248635].
57 Kjerulff KH, Langenberg PW, Rhodes JC, et al. Effectiveness of hysterectomy. Obstet Gynecol. Mar. 2000;95(3):319-26. [pmid: 10711536].
58 Kjerulff KH, Rhodes JC, Langenberg PW, et al. Patient satisfaction with results of hysterectomy. Am J Obstet Gynecol. Dec. 2000;183(6):1440-7. [pmid: 11120508].
59 Hillis SD, Marchbanks PA, Peterson HB. The effectiveness of hysterectomy for chronic pelvic pain. Obstet Gynecol. Dec. 1995;86(6):941-5. [pmid: 7501344].
60 Lee NC, Dicker RC, Rubin GL, et al. Confirmation of the preoperative diagnoses for hysterectomy. Am J Obstet Gynecol. Oct. 1. 1984;150(3):283-7. [pmid: 6486193].
61 Steege JF. Indications for hysterectomy: have they changed?. Clin Obstet Gynecol. Dec. 1997;40(4):878-85. [pmid: 9429801].
62 Ortiz DD. Chronic pelvic pain in women. Am Fam Physician. Jun. 1. 2008;77(11):1535-42. [pmid: 18581833].
63 Turner JA, Deyo RA, Loeser JD, et al. The importance of placebo effects in pain treatment and research. JAMA. May. 25. 1994;271(20):1609-14. [pmid: 7880221].
64 Moore RA, Gavaghan D, Tramer MR, et al. Size is everything--large amounts of information are needed to overcome random effects in estimating direction and magnitude of treatment effects. Pain. Dec. 1998;78(3):209-16. [pmid: 9870574].
65 Andrews J. Vulvodynia management: an evidence-based approach. J Clin Outcomes Manage. 2010;17(5):225-238.
66 Siler AC, Gardner H, Yanit K, et al. Systematic review of the comparative effectiveness of antiepileptic drugs for fibromyalgia. J Pain. Apr. 2011;12(4):407-15. [pmid: 21146466].
67 Vase L, Riley JL 3rd, Price DD. A comparison of placebo effects in clinical analgesic trials versus studies of placebo analgesia. Pain. Oct. 2002;99(3):443-52. [pmid: 12406519].
68 Dworkin RH, Turk DC, Wyrwich KW, et al. Interpreting the clinical importance of treatment outcomes in chronic pain clinical trials: IMMPACT recommendations. J Pain. Feb. 2008;9(2):105-21. [pmid: 18055266].
69 Owens DK, Lohr KN, Atkins D, et al. Grading the Strength of a Body of Evidence When Comparing Medical Interventions. 2008.
70 Lamvu G, Williams R, Zolnoun D, et al. Long-term outcomes after surgical and nonsurgical management of chronic pelvic pain: one year after evaluation in a pelvic pain specialty clinic. Am J Obstet Gynecol. Aug. 2006;195(2):591-8. discussion 598-600. [pmid: 16729951].
71 Sator-Katzenschlager SM, Scharbert G, Kress HG, et al. Chronic pelvic pain treated with gabapentin and amitriptyline: a randomized controlled pilot study. Wien Klin Wochenschr. Nov. 2005;117(21-22):761-8. [pmid: 16416358].
72 Williams RE, Hartmann KE, Sandler RS, et al. Prevalence and characteristics of irritable bowel syndrome among women with chronic pelvic pain. Obstet Gynecol. Sep. 2004;104(3):452-8. [pmid: 15339753].
73 Williams RE, Hartmann KE, Sandler RS, et al. Recognition and treatment of irritable bowel syndrome among women with chronic pelvic pain. Am J Obstet Gynecol. Mar. 2005;192(3):761-7. [pmid: 15746669].
74 Chung MH, Huh CY. Comparison of treatments for pelvic congestion syndrome. Tohoku J Exp Med. Nov. 2003;201(3):131-8. [pmid: 14649734].
75 Peters AA, van Dorst E, Jellis B, et al. A randomized clinical trial to compare two different approaches in women with chronic pelvic pain. Obstet Gynecol. May. 1991;77(5):740-4. [pmid: 1826544].
76 Droz J, Howard FM. Use of the Short-Form McGill Pain Questionnaire as a Diagnostic Tool in Women with Chronic Pelvic Pain. Journal of Minimally Invasive Gynecology. 2011;18(2):211-217. [pmid: 21354067].
77 Stratton P, Sinaii N, Segars J, et al. Return of chronic pelvic pain from endometriosis after raloxifene treatment: a randomized controlled trial. Obstet Gynecol. Jan. 2008;111(1):88-96. [pmid: 18165396].
78 Montenegro ML, Mateus-Vasconcelos EC, Rosa ESJC, et al. Postural changes in women with chronic pelvic pain: a case control study. BMC Musculoskelet Disord. 2009;10:82. [pmid: 19583850].
79 Pitts MK, Ferris JA, Smith AM, et al. Prevalence and correlates of three types of pelvic pain in a nationally representative sample of Australian women. Med J Aust. Aug. 4. 2008;189(3):138-43. [pmid: 18673099].
80 Johnson NP, Farquhar CM, Crossley S, et al. A double-blind randomised controlled trial of laparoscopic uterine nerve ablation for women with chronic pelvic pain. BJOG. Sep. 2004;111(9):950-9. [pmid: 15327610].
81 Ling FW. Randomized controlled trial of depot leuprolide in patients with chronic pelvic pain and clinically suspected endometriosis. Pelvic Pain Study Group. Obstet Gynecol. Jan. 1999;93(1):51-8. [pmid: 9916956].
82 Vercellini P, Trespidi L, Colombo A, et al. A gonadotropin-releasing hormone agonist versus a low-dose oral contraceptive for pelvic pain associated with endometriosis. Fertil Steril. Jul. 1993;60(1):75-9. [pmid: 8513962].
83 Gestrinone versus a gonadotropin-releasing hormone agonist for the treatment of pelvic pain associated with endometriosis: a multicenter, randomized, double-blind study. Gestrinone Italian Study Group. Fertil Steril. Dec. 1996;66(6):911-9. [pmid: 8941054].
84 Saravelos HG, Li TC, Cooke ID. An analysis of the outcome of microsurgical and laparoscopic adhesiolysis for chronic pelvic pain. Hum Reprod. Nov. 1995;10(11):2895-901. [pmid: 8747039].
85 Karp BI, Sinaii N, Nieman LK, et al. Migraine in women with chronic pelvic pain with and without endometriosis. Fertil Steril. 2010. Dec. 8.
86 Fenton BW, Palmieri P, Diantonio G, et al. Application of Patient-Reported Outcomes Measurement Information System to Chronic Pelvic Pain. Journal of Minimally Invasive Gynecology. 2011;18(2):189-193. [pmid: 21295528].
87 Fenton BW, Durner C, Fanning J. Frequency and distribution of multiple diagnoses in chronic pelvic pain related to previous abuse or drug-seeking behavior. Gynecol Obstet Invest. 2008;65(4):247-51. [pmid: 18196907].
88 Paulson JD, Delgado M. The relationship between interstitial cystitis and endometriosis in patients with chronic pelvic pain. JSLS. Apr-Jun. 2007;11(2):175-81. [pmid: 17761076].
89 Tu FF, As-Sanie S, Steege JF. Prevalence of pelvic musculoskeletal disorders in a female chronic pelvic pain clinic. J Reprod Med. Mar. 2006;51(3):185-9. [pmid: 16674013].
90 Bodden-Heidrich R, Kuppers V, Beckmann MW, et al. Psychosomatic aspects of vulvodynia. Comparison with the chronic pelvic pain syndrome. J Reprod Med. May. 1999;44(5):411-6. [pmid: 10360252].
91 Rein DB, Kassler WJ, Irwin KL, et al. Direct medical cost of pelvic inflammatory disease and its sequelae: decreasing, but still substantial. Obstet Gynecol. Mar. 2000;95(3):397-402. [pmid: 10711551].
92 Verit FF, Verit A, Yeni E. The prevalence of sexual dysfunction and associated risk factors in women with chronic pelvic pain: a cross-sectional study. Arch Gynecol Obstet. Aug. 2006;274(5):297-302. [pmid: 16705463].
93 Swank DJ, Swank-Bordewijk SC, Hop WC, et al. Laparoscopic adhesiolysis in patients with chronic abdominal pain: a blinded randomised controlled multi-centre trial. Lancet. Apr. 12. 2003;361(9365):1247-51. [pmid: 12699951].
94 Palomba S, Russo T, Falbo A, et al. Laparoscopic uterine nerve ablation versus vaginal uterosacral ligament resection in postmenopausal women with intractable midline chronic pelvic pain: a randomized study. Eur J Obstet Gynecol Reprod Biol. Nov. 2006;129(1):84-91. [pmid: 16442203].
95 Abbott JA, Jarvis SK, Lyons SD, et al. Botulinum toxin type A for chronic pain and pelvic floor spasm in women: a randomized controlled trial. Obstet Gynecol. Oct. 2006;108(4):915-23. [pmid: 17012454].
96 Heyman J, Ohrvik J, Leppert J. Distension of painful structures in the treatment for chronic pelvic pain in women. Acta Obstet Gynecol Scand. 2006;85(5):599-603. [pmid: 16752240].
97 Vercellini P, Barbara G, Somigliana E, et al. Comparison of contraceptive ring and patch for the treatment of symptomatic endometriosis. Fertil Steril. May. 1. 2010;93(7):2150-61. [pmid: 19328469].
98 Zupi E, Marconi D, Sbracia M, et al. Add-back therapy in the treatment of endometriosis-associated pain. Fertil Steril. Nov. 2004;82(5):1303-8. [pmid: 15533351].
99 Vercellini P, De Giorgi O, Oldani S, et al. Depot medroxyprogesterone acetate versus an oral contraceptive combined with very-low-dose danazol for long-term treatment of pelvic pain associated with endometriosis. Am J Obstet Gynecol. Aug. 1996;175(2):396-401. [pmid: 8765259].
100 Parazzini F, Di Cintio E, Chatenoud L, et al. Estroprogestin vs. gonadotrophin agonists plus estroprogestin in the treatment of endometriosis-related pelvic pain: a randomized trial. Gruppo Italiano per lo Studio dell'Endometriosi. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88(1):11-4. [pmid: 10659911].
101 Onwude JL, Thornton JG, Morley S, et al. A randomised trial of photographic reinforcement during postoperative counselling after diagnostic laparoscopy for pelvic pain. Eur J Obstet Gynecol Reprod Biol. Jan. 15. 2004;112(1):89-94. [pmid: 14687747].
102 Ghaly AFF. The psychological and physical benefits of pelvic ultrasonography in patients with chronic pelvic pain and negative laparoscopy. A random allocation trial. Journal of Obstetrics & Gynaecology. 1994;14:269-271.
103 Walton SM, Batra HK. The use of medroxyprogesterone acetate 50mg in the treatment of painful pelvic conditions: preliminary results from a multicentre trial. J Obstet Gynaecol. 1992;12(Suppl):S50-3.
104 Ye ZQ, Cai D, Lan RZ, et al. Biofeedback therapy for chronic pelvic pain syndrome. Asian J Androl. Jun. 2003;5(2):155-8. [pmid: 12778328].
105 Williams RE, Hartmann KE, Steege JF. Documenting the current definitions of chronic pelvic pain: implications for research. Obstet Gynecol. Apr. 2004;103(4):686-91. [pmid: 15051560].
106 Gallagher RM. Biopsychosocial pain medicine and mind-brain-body science. Phys Med Rehabil Clin N Am. Nov. 2004;15(4):855-82. vii. [pmid: 15458757].
107 Hyams JS. Irritable bowel syndrome, functional dyspepsia, and functional abdominal pain syndrome. Adolesc Med Clin. Feb. 2004;15(1):1-15. [pmid: 15272253].
108 Ong KS, Keng SB. The biological, social, and psychological relationship between depression and chronic pain. Cranio. Oct. 2003;21(4):286-94. [pmid: 14620702].
109 Turk DC, Okifuji A. Psychological factors in chronic pain: evolution and revolution. J Consult Clin Psychol. Jun. 2002;70(3):678-90. [pmid: 12090376].
110 Grace VM. Pitfalls of the medical paradigm in chronic pelvic pain. Baillieres Best Pract Res Clin Obstet Gynaecol. Jun. 2000;14(3):525-39. [pmid: 10962640].
111 Bradford A, Meston C. Correlates of placebo response in the treatment of sexual dysfunction in women: a preliminary report. J Sex Med. Sep. 2007;4(5):1345-51. [pmid: 17666035].
112 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb. 1. 1995;273(5):408-12. [pmid: 7823387].
113 Johnson AG. Surgery as a placebo. Lancet. Oct. 22. 1994;344(8930):1140-2. [pmid: 7934500].
114 Moseley JB, O'Malley K, Petersen NJ, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. Jul. 11. 2002;347(2):81-8. [pmid: 12110735].