# Peer Reviewers

Mary Lou Ballweg

President and Executive Director

Endometriosis Association

Milwaukee, WI

Georgine Lamvu, M.D., M.P.H., FACOG

Medical Director

Gynecologic Unit of Florida Hospital

Orlando, FL

Linda McGowan, Ph.D., M.Sc., B.Sc.

School of Nursing, Midwifery and Social Work

Faculty of Medical and Human Sciences

University of Manchester

Manchester, UK

Pamela Stratton, M.D.

Chief, Gynecology Consult Service

Pediatric and Reproductive Endocrinology Branch

National Institute of Child Health and Human Development (NICHD)

Bethesda, MD

Denniz Zolnoun, M.D., M.P.H.

Department of Obstetrics and Gynecology

University of North Carolina

Chapel Hill, NC