# Key Informants

Esther Eisenberg, M.D., M.P.H.

Project Scientist, Reproductive Medicine Network, National Institute of Child Health and Development

Department of Obstetrics and Gynecology, Vanderbilt Medical Center

Nashville, TN

Fred M. Howard, M.D.

Associate Chair, Academic Affairs

Director, Division of Obstetric/Gynecologic Specialties

Professor, Obstetrics and Gynecology

University of Rochester

Rochester, NY

Georgine Lamvu, M.D., M.P.H., FACOG

Medical Director

Gynecologic Unit of Florida Hospital

Orlando, FL

Bruce Lessey, M.D., Ph.D.

Vice Chair, Research

Center for Women’s Medicine, Greenville Hospital System

Greenville, SC

Kerri Schuiling, Ph.D., CNM, WHNP-BC

Associate Dean and Director, School of Nursing

Northern Michigan University

Marquette, MI

Eric Wall, M.D., M.P.H.

Senior Medical Director, Qualis Health

Seattle, WA

Rachel Williams, Ph.D.

Glaxo Smith Kline

Chapel Hill, NC

Denniz Zolnoun, M.D., M.P.H.

Department of Obstetrics and Gynecology

University of North Carolina

Chapel Hill, NC