# Ongoing and Recently Completed Intervention Studies

Table G1 Ongoing and recently completed CPP intervention studies