# Applicability Tables

Table F1 Applicability of evidence for LUNA

Population | The populations from studies examining the efficacy of LUNA represent highly selected populations within RCT protocols. Patients were generally recruited from tertiary care or academic centers, many with specialty pain clinics. Even between the three RCTs, the populations differed considerably based on different selection processes, with varying age restrictions, menopausal status, concomitant medical conditions (e.g., endometriosis) and thoroughness of preoperative analysis. Almost all randomized patients intraoperatively at the time of surgery, so these patients represent a specific group of women undergoing surgery for CPP. These findings may not be applicable to broader populations of women with CPP.
Intervention | LUNA is a common procedure for treatment of CPP, and its use may be applicable to many women with CPP
Comparators | The two comparators evaluated, diagnostic laparoscopy and uterosacral ligament resection, are both commonly performed procedures for diagnosis and treatment of CPP. Diagnostic laparoscopy is often a standard component of the evaluation process for CPP and its use is broadly applicable to the population at large.
Outcomes | The primary outcomes measured for all three studies were fairly consistent in the analysis of pain status recorded by VAS. However, interpretation and categorization of pain scores based on VAS was variable for studies. While VAS is a widely used measure of pain, the specific levels of measure may not be widely applicable to other populations of women with CPP.
Setting | All studies were performed at hospital settings that provide surgical expertise for laparoscopic procedures. Many of these were academic or referral centers specializing in CPP therapy. Generalization of these study findings to other settings may be limited.

Abbreviations: CPP = noncyclic chronic pelvic pain; LUNA = laparoscopic utero-sacral nerve ablation; RCT = randomized controlled trial; VAS = visual analog scale.

Table F2 Applicability of evidence for adhesiolysis

Population | The population recruited for the single study assessing the effectiveness of laparoscopic adhesiolysis was necessarily limited by the protocol for RCT, but was still fairly unrestricted in terms of age and associated medical conditions. The participants were limited to those thought to have adhesions from a previous abdominal surgery causing CPP, which was confirmed at the time of diagnostic laparoscopy. This specificity limits applicable to the broader population of women with CPP.
Intervention | The intervention studies, laparoscopic adhesiolysis, is a common procedure for the treatment of CPP and broadly applicable.
Comparators | The comparator procedure was diagnostic laparoscopy alone. This is a common procedure for the evaluation and treatment of women with CPP.
Outcomes | The primary outcome measured was change on VAS pain score, which is a common measure to quantify pain severity in women with CPP. Additionally, QOL was measured with the SF-36, which has been validated in and applied to many populations.
Setting | The surgical procedures were all performed at surgical facilities, but encompassed a range of settings, including teaching, non-teaching and university hospitals.

Abbreviations: CPP = noncyclic chronic pelvic pain; QOL = quality of life; RCT = randomized controlled trial; VAS = visual analog scale.

Table F3 Applicability of evidence for hysterectomy

Population | One study assessing the effect of hysterectomy on CPP recruited a broad population of women undergoing either hysterectomy or medical management for multiple reasons, including CPP. While the analysis focuses specifically on the subgroup of CPP patients, these patients likely represent a fairly non-selective cohort of women with CPP.
Intervention | Hysterectomy is a common procedure performed in women with or without CPP and would be applicable to a wide range of women with CPP.
Comparators | Medical therapy is a common approach to treating women with CPP and would be applicable to many women.
Outcomes | Measures used by the study to assess for change in pain status were not standard instruments, thus lacking validation. This may limit the applicability of the outcomes to other women with CPP undergoing hysterectomy or medical therapy.
Setting | The study was conducted in a wide variety of clinical settings, which would be applicable to many women with CPP.

Abbreviation: CPP = noncyclic chronic pelvic pain.

Table F4 Applicability of evidence for nonsurgical compared with surgical interventions

Population | In studies evaluating general surgical interventions comparing to non-surgical interventions for CPP, the populations are quite selected. One study examined a general cohort of women treated for CPP at a specialized referral clinic for CPP. The other enrolled women under an RCT protocol also after referral to specialized center. These populations are likely different from most women with CPP.
Intervention | Surgical intervention was broadly categorized in these studies, and included many different surgical techniques employed for the treatment of CPP.
Comparators | Non-surgical interventions included as comparators for the studies were varied. In one study, all patients treated with non-surgical approaches were grouped together, representing a heterogeneous group. In the other study, patients were administered a highly specific, intensive therapy which is not a mainstream approach to CPP treatment.
Outcomes | Outcomes for pain status were measured using the MPQ in both studies, which is a common tool for quantifying pain. However, interpretation and categorization of MPQ values were different for each trial and specific outcomes may not be broadly applicable.
Setting | The settings in which the studies were conducted ranged from community-based practices to university medical centers. This may allow for broad application of the findings.

Abbreviations: CPP = chronic pelvic pain; MPQ = McGill Pain Questionnaire; RCT = randomized controlled trial.

Table F5 Applicability of evidence for nonsurgical approaches

Population | Populations were largely from academic centers, and a majority of studies were conducted in Europe. Many studies included women with endometriosis-associated CPP.
Intervention | Many (8/15) studies focused on hormonal therapies; many require complex or multidisciplinary algorithms and close follow-up. Medication options across countries represented in the literature were inconsistent.
Comparators | Few studies were placebo-controlled; most assessed 2 or more active treatments.
Outcomes | Pain-related outcomes were typically assessed using a VAS. Few studies assessed quality of life or functionality.
Setting | The majority of studies were conducted in large academic centers with support systems, typically in Europe.

Abbreviations: CPP = noncyclic chronic pelvic pain; VAS = visual analog scale.