# Quality of the Literature

## Randomized Trials

Table E1 Quality of randomized controlled trials

Author, Year | Random assignment | Blinding--participants | Blinding--investigators | Blinding--providers | Blinding--assessors | Participant flow described | ITT analysis | Missing data adequately reported | Missing data managed acceptably | Primary outcome planned a priori | Free from bias | Sample size calculation provided | Appropriate statistical analysis | Statistical results reliable | < 10% drop-out rate | < 20% loss to follow-up | Final rating
Daniels 2009^1^ | + | + | - | - | - | + | + | + | + | + | + | + | + | + | + | - | Fair
Stratton 2008^2,3^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | Good
Heyman 2006^4^ | + | - | - | - | - | + | - | - | - | + | + | + | + | + | - | + | Poor
Palomba 2006 5 | + | - | - | - | - | + | - | - | - | - | + | + | + | + | + | + | Poor
Abbott 2006^6^ | + | + | + | - | - | + | - | + | - | + | + | + | + | + | + | + | Fair
Sator-Katzenschlager 2005^7^ | - | - | - | - | - | + | - | - | - | - | + | - | + | + | - | + | Poor
Onwude 2004^8^ | - | - | - | - | - | - | + | + | - | + | + | + | + | - | NA | - | Poor
Johnson 2004^9^ | - | + | - | - | - | + | + | - | - | + | + | + | + | + | + | + | Poor
Zupi 2004^10^ | + | - | - | - | - | - | NA | - | - | + | + | + | + | + | - | - | Poor
Swank 2003^11^ | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | Good
Parazzini 2000^12^ | + | - | - | - | - | - | + | + | - | + | + | - | + | + | - | - | Poor
Ling 1999^13^ | + | + | + | + | + | + | - | - | - | + | - | + | + | + | + | + | Fair
Vercellini 1996^14^ | + | - | - | - | - | + | + | - | - | + | + | + | + | + | - | - | Poor
Gestrinone Study Group1996^15^ | + | + | + | + | + | + | - | - | - | - | + | - | + | + | - | - | Poor
Ghaly 1994^16^ | - | - | - | - | + | - | - | - | - | + | + | - | - | - | + | + | Poor
Vercellini 1993^17^ | - | - | - | - | - | + | - | - | - | + | + | + | + | + | - | + | Poor
Walton 1992^18^ | - | - | - | - | - | + | - | + | - | - | - | + | - | - | - | - | Poor
Peters 1991^19^ | + | - | + | - | - | - | - | - | - | - | + | - | - | - | + | + | Poor

## Cohort Studies

Table E2 Quality of cohort studies

Author, Year | Participant characteristics described | Inclusion/exclusion criteria described | Criteria equally applied | Baseline comparability | Concurrent controls | Intervention clearly defined | Reliable measurement of intervention | Assessors blinded to intervention status | Avoidance of detection bias | Reliable outcome assessment methods | ≥ 12 weeks follow-up duration | Missing data adequately reported | Missed data managed adequately | Primary outcome planned a priori | Bias handling adequate | Substantive conflict of interest | Sample size calculation provided | Appropriate statistical analysis | Reliable statistical results | < 10% drop-out rate | < 20% loss to follow-up | Approach to confounders described | Adjustment for confounders adequate | Approach to effect modifiers described | Adequate adjustment for effect modifiers | Final Score
Vercellini 2010^20^ | + | + | + | + | + | + | NA | - | NA | + | + | + | - | + | + | + | + | + | + | - | - | + | + | - | - | Poor
Lamvu 2006^21^ | + | + | + | + | + | + | - | - | NA | + | + | + | NA | + | + | + | - | + | + | - | - | + | + | + | + | Poor
Carlson 1994^22^ | + | + | + | - | + | - | - | - | NA | - | + | - | - | + | - | - | - | - | - | - | - | + | + | + | + | Poor

## Studies Addressing Prevalence of Comorbidities of Interest

Table E3 Quality of studies addressing prevalence of comorbidities of interest

Author, Year | Sampling method adequate | Sample size > 100 | Response rate > 70% | Inclusion/exclusion criteria specified | Validated diagnostic criteria for comorbidity | Operational definition provided | Final Score
Back Pain
Droz 2011^23^ | + | + | NA | + | - | + | Fair
Lamvu 2006^21^ | + | + | NA | + | - | - | Poor
Grace 2005^24,25^ | + | + | - | + | - | - | Poor
Sator-Katzenschlager 2005^7^ | + | - | NA | + | + | NA | Fair
Williams 2004^26,27^ | + | + | + | + | - | - | Poor
Chung 2003^28^ | + | + | NA | + | - | - | Poor
Zondervan 2001^29^ | + | + | + | + | - | - | Poor
Peters 1991^19^ | + | + | NA | + | - | - | Poor
Depression
Stratton 2008^2,3^ | + | + | NA | + | - | - | Poor
Lamvu 2006^21^ | + | + | NA | + | + | NA | Good
Williams 2004^26,27^ | + | + | + | + | + | NA | Good
Dysmenorrhea
Droz 2011^23^ | + | + | NA | + | - | + | Fair
Montenegro 2009^30^ | - | + | + | + | - | + | Poor
Pitts 2008^31^ | + | + | - | + | - | + | Poor
Grace 2005^24,25^ | + | + | - | + | - | + | Poor
Johnson 2004^9^ | + | + | NA | + | - | + | Poor
Chung 2003^28^ | + | + | NA | + | - | - | Poor
Zondervan 2001^29^ | + | + | + | + | - | + | Fair
Ling 1999^13^ | + | + | NA | + | - | - | Poor
Gestrinone Study Group 1996^15^ | + | - | NA | + | - | + | Poor
Vercellini 1993^17^ | - | - | NA | + | - | + | Poor
Dyspareunia
Montenegro 2009^30^ | - | + | + | + | - | + | Poor
Pitts 2008^31^ | + | + | - | + | - | + | Poor
Grace 2005^24,25^ | + | + | - | + | - | + | Poor
Johnson 2004^9^ | + | + | NA | + | - | + | Poor
Williams 2004^26,27^ | + | + | + | + | - | - | Poor
Chung 2003^28^ | + | + | NA | + | - | - | Poor
Zondervan 2001^29^ | + | + | + | + | - | + | Fair
Matthias 1996^32^ | + | + | + | + | - | + | Fair
Ling 1999^13^ | + | + | NA | + | - | - | Poor
Gestrinone Study Group 1996^15^ | + | - | NA | + | - | + | Poor
Saravelos 1995^33^ | - | + | NA | + | - | - | Poor
Peters 1991^19^ | + | + | NA | + | - | - | Poor
Headache
Stratton 2008^2,3^ | + | + | NA | + | - | - | Poor
Peters 1991^19^ | + | + | NA | + | - | - | Poor
Interstitial cystitis
Droz 2011^23^ | + | + | NA | + | - | + | Fair
Fenton 2011^34^ | + | + | NA | + | - | + | Fair
Paulson 2007^35^ | + | + | NA | + | - | + | Fair
Fenton 2008^36^ | + | + | NA | + | + | - | Good
Irritable bowel syndrome
Droz 2011^23^ | + | + | NA | + | + | NA | Good
Fenton 2011^34^ | + | + | NA | + | - | + | Fair
Fenton 2008^36^ | + | + | NA | + | + | NA | Good
Lamvu 2006^21^ | + | + | NA | + | - | - | Poor
Tu 2006^37^ | - | + | NA | + | + | NA | Fair
Grace 2005^24,25^ | + | + | - | + | + | NA | Fair
Sator-Katzenschlager 2005^7^ | + | - | NA | + | - | - | Poor
Williams 2004^26,27^ | + | + | + | + | + | NA | Good
Zondervan 2001^29^ | + | + | + | + | + | NA | Good
Bodden-Heidrich 1999^38^ | - | + | NA | + | - | - | Poor
Migraine
Stratton 2008^2,3^ | + | + | NA | + | + | NA | Good
Sexual dysfunction
Lamvu 2006^21^ | + | + | NA | + | - | - | Poor
Verit 2006^39^ | - | + | + | + | + | NA | Fair
Grace 2005^24,25^ | + | + | - | + | - | - | Poor
Williams 2004^26,27^ | + | + | + | + | - | - | Poor
Peters 1991^19^ | + | + | NA | + | - | - | Poor
Vulvodynia
Droz 2011^23^ | + | + | NA | + | - | + | Fair
Fenton 2011^34^ | + | + | NA | + | - | + | Fair
Fenton 2008^36^ | + | + | NA | + | - | + | Poor
Lamvu 2006^21^ | + | + | NA | + | - | - | Poor

## Appendix E References

1 Daniels J, Gray R, Hills RK, et al. Laparoscopic uterosacral nerve ablation for alleviating chronic pelvic pain: a randomized controlled trial. JAMA. Sep. 2. 2009;302(9):955-61. [pmid: 19724042].
2 Stratton P, Sinaii N, Segars J, et al. Return of chronic pelvic pain from endometriosis after raloxifene treatment: a randomized controlled trial. Obstet Gynecol. Jan. 2008;111(1):88-96. [pmid: 18165396].
3 Karp BI, Sinaii N, Nieman LK, et al. Migraine in women with chronic pelvic pain with and without endometriosis. Fertil Steril. 2010. Dec. 8.
4 Heyman J, Ohrvik J, Leppert J. Distension of painful structures in the treatment for chronic pelvic pain in women. Acta Obstet Gynecol Scand. 2006;85(5):599-603. [pmid: 16752240].
5 Palomba S, Russo T, Falbo A, et al. Laparoscopic uterine nerve ablation versus vaginal uterosacral ligament resection in postmenopausal women with intractable midline chronic pelvic pain: a randomized study. Eur J Obstet Gynecol Reprod Biol. Nov. 2006;129(1):84-91. [pmid: 16442203].
6 Abbott JA, Jarvis SK, Lyons SD, et al. Botulinum toxin type A for chronic pain and pelvic floor spasm in women: a randomized controlled trial. Obstet Gynecol. Oct. 2006;108(4):915-23. [pmid: 17012454].
7 Sator-Katzenschlager SM, Scharbert G, Kress HG, et al. Chronic pelvic pain treated with gabapentin and amitriptyline: a randomized controlled pilot study. Wien Klin Wochenschr. Nov. 2005;117(21-22):761-8. [pmid: 16416358].
8 Onwude JL, Thornton JG, Morley S, et al. A randomised trial of photographic reinforcement during postoperative counselling after diagnostic laparoscopy for pelvic pain. Eur J Obstet Gynecol Reprod Biol. Jan. 15. 2004;112(1):89-94. [pmid: 14687747].
9 Johnson NP, Farquhar CM, Crossley S, et al. A double-blind randomised controlled trial of laparoscopic uterine nerve ablation for women with chronic pelvic pain. BJOG. Sep. 2004;111(9):950-9. [pmid: 15327610].
10 Zupi E, Marconi D, Sbracia M, et al. Add-back therapy in the treatment of endometriosis-associated pain. Fertil Steril. Nov. 2004;82(5):1303-8. [pmid: 15533351].
11 Swank DJ, Swank-Bordewijk SC, Hop WC, et al. Laparoscopic adhesiolysis in patients with chronic abdominal pain: a blinded randomised controlled multi-centre trial. Lancet. Apr. 12. 2003;361(9365):1247-51. [pmid: 12699951].
12 Parazzini F, Di Cintio E, Chatenoud L, et al. Estroprogestin vs. gonadotrophin agonists plus estroprogestin in the treatment of endometriosis-related pelvic pain: a randomized trial. Gruppo Italiano per lo Studio dell'Endometriosi. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88(1):11-4. [pmid: 10659911].
13 Ling FW. Randomized controlled trial of depot leuprolide in patients with chronic pelvic pain and clinically suspected endometriosis. Pelvic Pain Study Group. Obstet Gynecol. Jan. 1999;93(1):51-8. [pmid: 9916956].
14 Vercellini P, De Giorgi O, Oldani S, et al. Depot medroxyprogesterone acetate versus an oral contraceptive combined with very-low-dose danazol for long-term treatment of pelvic pain associated with endometriosis. Am J Obstet Gynecol. Aug. 1996;175(2):396-401. [pmid: 8765259].
15 Gestrinone versus a gonadotropin-releasing hormone agonist for the treatment of pelvic pain associated with endometriosis: a multicenter, randomized double-blind study. Gestrinone Italian Study Group. Fertil Steril. Dec. 1996;66(6):911-9. [pmid: 8941054].
16 Ghaly AFF. The psychological and physical benefits of pelvic ultrasonography in patients with chronic pelvic pain and negative laparoscopy. A random allocation trial. Journal of Obstetrics & Gynaecology. 1994;14:269-271.
17 Vercellini P, Trespidi L, Colombo A, et al. A gonadotropin-releasing hormone agonist versus a low-dose oral contraceptive for pelvic pain associated with endometriosis. Fertil Steril. Jul. 1993;60(1):75-9. [pmid: 8513962].
18 Walton SM, Batra HK. The use of medroxyprogesterone acetate 50mg in the treatment of painful pelvic conditions: preliminary results from a multicentre trial. J Obstet Gynaecol. 1992;12(Suppl):S50-3.
19 Peters AA, van Dorst E, Jellis B, et al. A randomized clinical trial to compare two different approaches in women with chronic pelvic pain. Obstet Gynecol. May. 1991;77(5):740-4. [pmid: 1826544].
20 Vercellini P, Barbara G, Somigliana E, et al. Comparison of contraceptive ring and patch for the treatment of symptomatic endometriosis. Fertil Steril. May. 1. 2010;93(7):2150-61. [pmid: 19328469].
21 Lamvu G, Williams R, Zolnoun D, et al. Long-term outcomes after surgical and nonsurgical management of chronic pelvic pain: one year after evaluation in a pelvic pain specialty clinic. Am J Obstet Gynecol. Aug. 2006;195(2):591-8. discussion 598-600. [pmid: 16729951].
22 Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women's Health Study: II. Outcomes of nonsurgical management of leiomyomas, abnormal bleeding, and chronic pelvic pain. Obstet Gynecol. Apr. 1994;83(4):566-72. [pmid: 8134067].
23 Droz J, Howard FM. Use of the Short-Form McGill Pain Questionnaire as a Diagnostic Tool in Women with Chronic Pelvic Pain. Journal of Minimally Invasive Gynecology. 2011;18(2):211-217. [pmid: 21354067].
24 Grace V, Zondervan K. Chronic pelvic pain in women in New Zealand: comparative well-being, comorbidity, and impact on work and other activities. Health Care Women Int. Aug. 2006;27(7):585-99. [pmid: 16844672].
25 Grace VM, Zondervan KT. Chronic pelvic pain in New Zealand: prevalence, pain severity, diagnoses and use of the health services. Aust N Z J Public Health. Aug. 2004;28(4):369-75. [pmid: 15704703].
26 Williams RE, Hartmann KE, Sandler RS, et al. Recognition and treatment of irritable bowel syndrome among women with chronic pelvic pain. Am J Obstet Gynecol. Mar. 2005;192(3):761-7. [pmid: 15746669].
27 Williams RE, Hartmann KE, Sandler RS, et al. Prevalence and characteristics of irritable bowel syndrome among women with chronic pelvic pain. Obstet Gynecol. Sep. 2004;104(3):452-8. [pmid: 15339753].
28 Chung MH, Huh CY. Comparison of treatments for pelvic congestion syndrome. Tohoku J Exp Med. Nov. 2003;201(3):131-8. [pmid: 14649734].
29 Zondervan KT, Yudkin PL, Vessey MP, et al. Chronic pelvic pain in the community--symptoms, investigations, and diagnoses. Am J Obstet Gynecol. May. 2001;184(6):1149-55. [pmid: 11349181].
30 Montenegro ML, Mateus-Vasconcelos EC, Rosa ESJC, et al. Postural changes in women with chronic pelvic pain: a case control study. BMC Musculoskelet Disord. 2009;10:82. [pmid: 19583850].
31 Pitts MK, Ferris JA, Smith AM, et al. Prevalence and correlates of three types of pelvic pain in a nationally representative sample of Australian women. Med J Aust. Aug. 4. 2008;189(3):138-43. [pmid: 18673099].
32 Mathias SD, Kuppermann M, Liberman RF, et al. Chronic pelvic pain: prevalence, health-related quality of life, and economic correlates. Obstet Gynecol. Mar. 1996;87(3):321-7. [pmid: 8598948].
33 Saravelos HG, Li TC, Cooke ID. An analysis of the outcome of microsurgical and laparoscopic adhesiolysis for chronic pelvic pain. Hum Reprod. Nov. 1995;10(11):2895-901. [pmid: 8747039].
34 Fenton BW, Palmieri P, Diantonio G, et al. Application of Patient-Reported Outcomes Measurement Information System to Chronic Pelvic Pain. Journal of Minimally Invasive Gynecology. 2011;18(2):189-193. [pmid: 21295528].
35 Paulson JD, Delgado M. The relationship between interstitial cystitis and endometriosis in patients with chronic pelvic pain. JSLS. Apr-Jun. 2007;11(2):175-81. [pmid: 17761076].
36 Fenton BW, Durner C, Fanning J. Frequency and distribution of multiple diagnoses in chronic pelvic pain related to previous abuse or drug-seeking behavior. Gynecol Obstet Invest. 2008;65(4):247-51. [pmid: 18196907].
37 Tu FF, As-Sanie S, Steege JF. Prevalence of pelvic musculoskeletal disorders in a female chronic pelvic pain clinic. J Reprod Med. Mar. 2006;51(3):185-9. [pmid: 16674013].
38 Bodden-Heidrich R, Kuppers V, Beckmann MW, et al. Psychosomatic aspects of vulvodynia. Comparison with the chronic pelvic pain syndrome. J Reprod Med. May. 1999;44(5):411-6. [pmid: 10360252].
39 Verit FF, Verit A, Yeni E. The prevalence of sexual dysfunction and associated risk factors in women with chronic pelvic pain: a cross-sectional study. Arch Gynecol Obstet. Aug. 2006;274(5):297-302. [pmid: 16705463].