# Data Extraction Forms

Therapies for Women with Chronic Pelvic Pain: Abstract Review Form

Therapies for Women with CPP CER: Full Text Review Form