# Evidence Tables

Evidence Tables Therapies for women with noncyclic chronic pelvic pain