# Excluded Studies

Exclusion Reasons:

X-1 Not original research
X-2 Population not applicable
X-3 Ineligible study size
X-4 Does not address key questions
X-5 Does not include relevant outcomes
X-6 Not published in English

1 Wu MH, et al. Prostaglandin E2: the master of endometriosis?. Exp Biol Med (Maywood). 2010;235(6):668-77. X-1, X-2, X-3, X-4. [pmid: 20511671].
2 Kukura V, et al. Alcohol sclerosing ovarian cystic lesions, 20 years experience. Coll Antropol. 2010;34(1):37-40. X-2, X-3, X-4, X-5. [pmid: 20432731].
3 Santosh A, et al. Chronic pelvic pain: a dilemma. J Pak Med Assoc. 2010;60(4):257-60. X-3. [pmid: 20419964].
4 Dousset B, et al. Complete surgery for low rectal endometriosis: long-term results of a 100-case prospective study. Ann Surg. 2010;251(5):887-95. X-3. [pmid: 20395847].
5 Shoskes DA, Nickel JC, Kattan MW. Phenotypically directed multimodal therapy for chronic prostatitis/chronic pelvic pain syndrome: a prospective study using UPOINT. Urology. 2010;75(6):1249-53. X-2, X-3, X-4. [pmid: 20363491].
6 McDonald-Mosley R, Burke AE. Contraceptive implants. Semin Reprod Med. 2010;28(2):110-7. X-1, X-2, X-3, X-4, X-5. [pmid: 20352560].
7 de Bernardes NO, et al. Use of intravaginal electrical stimulation for the treatment of chronic pelvic pain: a randomized, double-blind, crossover clinical trial. J Reprod Med. 2010;55(1-2):19-24. X-3. [pmid: 20337203].
8 Shah DK, et al. Public perceptions of endometriosis: perspectives from both genders. Acta Obstet Gynecol Scand. 2010;89(5):646-50. X-2, X-4. [pmid: 20235893].
9 Abercrombie P. Providing holistic care for women with chronic pelvic pain. Beginnings. 2010;30(1):20-1. X-1, X-2, X-3, X-4. [pmid: 20192014].
10 Luce H, Schrager S, Gilchrist V. Sexual assault of women. Am Fam Physician. 2010;81(4):489-95. X-1, X-2, X-3, X-4, X-5. [pmid: 20148503].
11 Mao AJ, Anastasi JK. Diagnosis and management of endometriosis: the role of the advanced practice nurse in primary care. J Am Acad Nurse Pract. 2010;22(2):109-16. X-1, X-2, X-3, X-4. [pmid: 20132369].
12 Chapron C, et al. Surgery for bladder endometriosis: long-term results and concomitant management of associated posterior deep lesions. Hum Reprod. 2010;25(4):884-9. X-2, X-3. [pmid: 20129993].
13 Camanni M, et al. Hysteroscopic management of large symptomatic submucous uterine myomas. J Minim Invasive Gynecol. 2010;17(1):59-65. X-2, X-3, X-4, X-5. [pmid: 20129334].
14 Roman JD. Surgical treatment of endometriosis in private practice: cohort study with mean follow-up of 3 years. J Minim Invasive Gynecol. 2010;17(1):42-6. X-2, X-3. [pmid: 20129331].
15 Roman H, et al. Delayed functional outcomes associated with surgical management of deep rectovaginal endometriosis with rectal involvement: giving patients an informed choice. Hum Reprod. 2010;25(4):890-9. X-3. [pmid: 20106836].
16 McGowan L, et al. Is chronic pelvic pain a comfortable diagnosis for primary care practitioners: a qualitative study. BMC Fam Pract. 2010;11:7. X-1, X-2, X-3, X-4, X-5. [pmid: 20105323].
17 Ansari NN, et al. Low back pain during pregnancy in Iranian women: Prevalence and risk factors. Physiother Theory Pract. 2010;26(1):40-8. X-2, X-3, X-4, X-5. [pmid: 20067352].
18 Chelli D, et al. Pelvic hydatid (echinococcal) disease. Int J Gynaecol Obstet. 2010;109(1):45-8. X-2, X-3, X-4. [pmid: 20022597].
19 Langenberg PW, et al. Pelvic pain and surgeries in women before interstitial cystitis/painful bladder syndrome. Am J Obstet Gynecol. 2010;202(3):286 e1-6. X-2, X-3, X-4, X-5. [pmid: 20022588].
20 Zhu L, et al. Epidemiology of mixed urinary incontinence in China. Int J Gynaecol Obstet. 2010;109(1):55-8. X-2, X-3, X-4, X-5. [pmid: 20022321].
21 Tarjanne S, Sjoberg J, Heikinheimo O. Radical excision of rectovaginal endometriosis results in high rate of pain relief - results of a long-term follow-up study. Acta Obstet Gynecol Scand. 2010;89(1):71-7. X-2, X-3, X-4. [pmid: 20021267].
22 Sanchez Freire V, et al. MicroRNAs may mediate the down-regulation of neurokinin-1 receptor in chronic bladder pain syndrome. Am J Pathol. 2010;176(1):288-303. X-2, X-3, X-4, X-5. [pmid: 20008142].
23 Ahn AC, et al. Electrodermal measures of Jing-Well points and their clinical relevance in endometriosis-related chronic pelvic pain. J Altern Complement Med. 2009;15(12):1293-305. X-4. [pmid: 19958132].
24 Beales DJ, O'Sullivan PB, Briffa NK. The effects of manual pelvic compression on trunk motor control during an active straight leg raise in chronic pelvic girdle pain subjects. Man Ther. 2010;15(2):190-9. X-3, X-4. [pmid: 19945907].
25 Butrick CW. Pelvic floor hypertonic disorders: identification and management. Obstet Gynecol Clin North Am. 2009;36(3):707-22. X-1, X-2, X-3, X-4. [pmid: 19932423].
26 Butrick CW. Pathophysiology of pelvic floor hypertonic disorders. Obstet Gynecol Clin North Am. 2009;36(3):699-705. X-1, X-2, X-3, X-4. [pmid: 19932422].
27 Kang JL, et al. Efficacy of gonadotropin-releasing hormone agonist and an extended-interval dosing regimen in the treatment of patients with adenomyosis and endometriosis. Gynecol Obstet Invest. 2010;69(2):73-7. X-2, X-3, X-4, X-5. [pmid: 19923847].
28 Wingenfeld K, et al. HPA axis reactivity in chronic pelvic pain: association with depression. J Psychosom Obstet Gynaecol. 2009;30(4):282-6. X-3. [pmid: 19922402].
29 Hedelin HH. Evaluation of a modification of the UPOINT clinical phenotype system for the chronic pelvic pain syndrome. Scand J Urol Nephrol. 2009;43(5):373-6. X-2, X-3, X-4,. [pmid: 19921982].
30 Neis KJ, Neis F. Chronic pelvic pain: cause, diagnosis and therapy from a gynaecologist's and an endoscopist's point of view. Gynecol Endocrinol. 2009;25(11):757-61. X-1, X-2, X-3, X-4, X-5. [pmid: 19908952].
31 Bersinger NA, et al. Effect of peritoneal fluid from endometriosis patients on neuroblastoma cells in culture. Gynecol Endocrinol. 2009;25(11):707-12. X-2, X-3, X-4, X-5. [pmid: 19908949].
32 Szendei GA. Endometriosis in Hungary. Gynecol Endocrinol. 2009;25(11):694-700. X-1, X-2, X-3, X-4, X-5. [pmid: 19903047].
33 Yilmaz U, et al. Sensory perception thresholds in men with chronic pelvic pain syndrome. Urology. 2010;75(1):34-7. X-2, X-3, X-4. [pmid: 19854487].
34 Anderson RU, et al. Painful myofascial trigger points and pain sites in men with chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2009;182(6):2753-8. X-2, X-3, X-4. [pmid: 19837420].
35 Jin KN, et al. Venous reflux from the pelvis and vulvoperineal region as a possible cause of lower extremity varicose veins: diagnosis with computed tomographic and ultrasonographic findings. J Comput Assist Tomogr. 2009;33(5):763-9. X-3, X-4. [pmid: 19820508].
36 Ferrero S, et al. Norethisterone acetate in the treatment of colorectal endometriosis: a pilot study. Hum Reprod. 2010;25(1):94-100. X-3. [pmid: 19820247].
37 Fukui Y, et al. A metabonomic approach identifies human urinary phenylacetylglutamine as a novel marker of interstitial cystitis. J Chromatogr B Analyt Technol Biomed Life Sci. 2009;877(30):3806-12. X-2, X-3, X-4, X-5.
38 Bai J, et al. Characterization of circulating CD4+CD25high regulatory T cells in men with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2010;75(4):938-42. X-2, X-3, X-4. [pmid: 19800664].
39 Clemens JQ, et al. Validation of a modified National Institutes of Health chronic prostatitis symptom index to assess genitourinary pain in both men and women. Urology. 2009;74(5):983-7. quiz 987 e1-3. X-2, X-3, X-4, X-5. [pmid: 19800663].
40 Zhao WP, et al. Celecoxib reduces symptoms in men with difficult chronic pelvic pain syndrome (Category IIIA). Braz J Med Biol Res. 2009;42(10):963-7. X-2, X-3, X-4. [pmid: 19787151].
41 Khawaja M, et al. Symptoms of reproductive tract infections and mental distress among women in low-income urban neighborhoods of Beirut, Lebanon. J Womens Health (Larchmt). 2009;18(10):1701-8. X-2, X-3, X-4, X-5. [pmid: 19785571].
42 Kouiavskaia DV, et al. T-cell recognition of prostatic peptides in men with chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2009;182(5):2483-9. X-2, X-3, X-4. [pmid: 19765754].
43 Anderson RU, et al. Stress induced hypothalamus-pituitary-adrenal axis responses and disturbances in psychological profiles in men with chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2009;182(5):2319-24. X-2, X-3, X-4. [pmid: 19762053].
44 Taylor-Robinson D, et al. Further observations, mainly serological, on a cohort of women with or without pelvic inflammatory disease. Int J STD AIDS. 2009;20(10):712-8. X-4. [pmid: 19759049].
45 Fabbri E, et al. McGill Pain Questionnaire: a multi-dimensional verbal scale assessing postoperative changes in pain symptoms associated with severe endometriosis. J Obstet Gynaecol Res. 2009;35(4):753-60. X-2, X-3. [pmid: 19751338].
46 Al-Azemi M, et al. Immediate and delayed add-back hormonal replacement therapy during ultra long GnRH agonist treatment of chronic cyclical pelvic pain. BJOG. 2009;116(12):1646-56. X-2, X-3, X-4. [pmid: 19735378].
47 Govindan S, et al. Estrogen receptor-alpha gene (T/C) Pvu II polymorphism in endometriosis and uterine fibroids. Dis Markers. 2009;26(4):149-54. X-2, X-3, X-4, X-5. [pmid: 19729795].
48 Ferrero S, et al. Letrozole combined with norethisterone acetate compared with norethisterone acetate alone in the treatment of pain symptoms caused by endometriosis. Hum Reprod. 2009;24(12):3033-41. X-2, X-3. [pmid: 19726448].
49 Ellem SJ, et al. Increased endogenous estrogen synthesis leads to the sequential induction of prostatic inflammation (prostatitis) and prostatic pre-malignancy. Am J Pathol. 2009;175(3):1187-99. X-2, X-3, X-4. [pmid: 19700748].
50 Yuan P, et al. Induction of a local pseudo-pregnancy for the treatment of endometriosis. Med Hypotheses. 2010;74(1):56-8. X-1, X-2, X-3. [pmid: 19699590].
51 Seear K. The etiquette of endometriosis: stigmatisation, menstrual concealment and the diagnostic delay. Soc Sci Med. 2009;69(8):1220-7. X-1, X-2, X-3, X-4. [pmid: 19699572].
52 Refaat B, et al. Role of activins and inducible nitric oxide in the pathogenesis of ectopic pregnancy in patients with or without Chlamydia trachomatis infection. Clin Vaccine Immunol. 2009;16(10):1493-503. X-2, X-3, X-4. [pmid: 19692623].
53 Hatchett L, et al. Life impact of urologic pain syndromes. J Health Psychol. 2009;14(6):741-50. X-2, X-3, X-4, X-5. [pmid: 19687111].
54 Aslam N, et al. Visceral hyperalgesia in chronic pelvic pain. BJOG. 2009;116(12):1551-5. X-1, X-2, X-3, X-4, X-5. [pmid: 19681848].
55 Broach AN, Mansuria SM, Sanfilippo JS. Pediatric and adolescent gynecologic laparoscopy. Clin Obstet Gynecol. 2009;52(3):380-9. X-1, X-2, X-3, X-4. [pmid: 19661754].
56 Doyle JO, Missmer SA, Laufer MR. The effect of combined surgical-medical intervention on the progression of endometriosis in an adolescent and young adult population. J Pediatr Adolesc Gynecol. 2009;22(4):257-63. X-3, X-5. [pmid: 19646673].
57 Kabay S, et al. Efficiency of posterior tibial nerve stimulation in category IIIB chronic prostatitis/chronic pelvic pain: a Sham-Controlled Comparative Study. Urol Int. 2009;83(1):33-8. X-2, X-3, X-4. [pmid: 19641356].
58 Pitsos M, Skurnick J, Heller D. Association of pathologic diagnoses with clinical findings in chronic endometritis. J Reprod Med. 2009;54(6):373-7. X-2, X-3, X-4, X-5. [pmid: 19639927].
59 Ferrero S, et al. Uterine adenomyosis in persistence of dysmenorrhea after surgical excision of pelvic endometriosis and colorectal resection. J Reprod Med. 2009;54(6):366-72. X-2, X-3, X-4. [pmid: 19639926].
60 Gentilini D, et al. Plasminogen activator inhibitor-1 4G/5G polymorphism and susceptibility to endometriosis in the Italian population. Eur J Obstet Gynecol Reprod Biol. 2009;146(2):219-21. X-3, X-4, X-5. [pmid: 19608328].
61 Oh TH, Ryu DS. Transurethral resection of intravesical mesh after midurethral sling procedures. J Endourol. 2009;23(8):1333-7. X-2, X-3, X-4, X-5. [pmid: 19591616].
62 Brandsborg B, et al. A prospective study of risk factors for pain persisting 4 months after hysterectomy. Clin J Pain. 2009;25(4):263-8. X-3. [pmid: 19590472].
63 Bendana EE, et al. Efficacy of transvaginal biofeedback and electrical stimulation in women with urinary urgency and frequency and associated pelvic floor muscle spasm. Urol Nurs. 2009;29(3):171-6. X-2, X-3, X-4. [pmid: 19579410].
64 Asciutto G, et al. Pelvic venous incompetence: reflux patterns and treatment results. Eur J Vasc Endovasc Surg. 2009;38(3):381-6. X-2, X-3, X-4, X-5. [pmid: 19574069].
65 Pereira RM, et al. Should the gynecologist perform laparoscopic bowel resection to treat endometriosis? Results over 7 years in 168 patients. J Minim Invasive Gynecol. 2009;16(4):472-9. X-2, X-3. [pmid: 19573824].
66 Bernal RM, Pontari MA. Evaluation of chronic pelvic pain syndrome in men: is it chronic prostatitis?. Curr Urol Rep. 2009;10(4):295-301. X-1, X-2, X-3, X-4. [pmid: 19570491].
67 Potts JM. Nonpharmacological approaches for the treatment of urological chronic pelvic pain syndromes in men. Curr Urol Rep. 2009;10(4):289-94. X-1, X-2, X-3, X-4. [pmid: 19570490].
68 Ferris JA, et al. National prevalence of urogenital pain and prostatitis-like symptoms in Australian men using the National Institutes of Health Chronic Prostatitis Symptoms Index. BJU Int. 2010;105(3):373-9. X-2, X-3, X-4. [pmid: 19549116].
69 Fenton BW, et al. Quantification of abdominal wall pain using pain pressure threshold algometry in patients with chronic pelvic pain. Clin J Pain. 2009;25(6):500-5. X-3. [pmid: 19542798].
70 Rackow BW, et al. Interstitial cystitis is an etiology of chronic pelvic pain in young women. J Pediatr Adolesc Gynecol. 2009;22(3):181-5. X-3. [pmid: 19539205].
71 Roya R, Baludu GS, Reddy BS. Possible aggravating impact of gene polymorphism in women with endometriosis. Indian J Med Res. 2009;129(4):395-400. X-2, X-3, X-4, X-5. [pmid: 19535834].
72 FitzGerald MP, et al. Randomized multicenter feasibility trial of myofascial physical therapy for the treatment of urological chronic pelvic pain syndromes. J Urol. 2009;182(2):570-80. X-2, X-3, X-4, X-5. [pmid: 19535099].
73 Sivanesaratnam V, Third SS. Ratnam memorial lecture 2007. Ovarian cancer: Is there hope for women?. J Obstet Gynaecol Res. 2009;35(3):393-404. X-1, X-2, X-3, X-4. [pmid: 19527374].
74 Wagenlehner FM, et al. A pollen extract (Cernilton) in patients with inflammatory chronic prostatitis-chronic pelvic pain syndrome: a multicentre, randomised, prospective, double-blind, placebo-controlled phase 3 study. Eur Urol. 2009;56(3):544-51. X-2, X-3, X-4. [pmid: 19524353].
75 Clemens JQ, et al. Rescoring the NIH chronic prostatitis symptom index: nothing new. Prostate Cancer Prostatic Dis. 2009;12(3):285-7. X-2, X-3, X-4. [pmid: 19488065].
76 Denny E. I never know from one day to another how I will feel: pain and uncertainty in women with endometriosis. Qual Health Res. 2009;19(7):985-95. X-3, X-4. [pmid: 19470614].
77 Butrick CW, et al. Chronic pelvic pain syndromes: clinical, urodynamic, and urothelial observations. Int Urogynecol J Pelvic Floor Dysfunct. 2009;20(9):1047-53. X-2, X-3. [pmid: 19458891].
78 Chapa HO, et al. In-office endometrial ablation and clinical correlation of reduced menstrual blood loss and effects on dysmenorrhea and premenstrual symptomatology. J Reprod Med. 2009;54(4):232-8. X-2, X-3, X-4, X-5. [pmid: 19438165].
79 Peng H, Chen Q, Tan Y. Frequent ejaculation associated free radical and lactic acid accumulation cause noninfectious inflammation and muscle dysfunction: a potential mechanism for symptoms in Chronic Prostatitis/Chronic Pelvic Pain Syndrome. Med Hypotheses. 2009;73(3):372-3. X-1, X-2, X-3, X-4. [pmid: 19435656].
80 Skerk V, et al. Comparison of clinical symptoms scored according to the National Institutes of Health chronic prostatitis symptoms index and assessment of antimicrobial treatment in patients with chronic prostatitis syndrome. J Chemother. 2009;21(2):181-7. X-2, X-3, X-4. [pmid: 19423471].
81 Trehan AK, Sanaullah F. Laparoscopic posthysterectomy vaginal vault excision for chronic pelvic pain and deep dyspareunia. J Minim Invasive Gynecol. 2009;16(3):326-32. X-3. [pmid: 19423063].
82 Park C, Overton C. GPs have a vital role in managing pelvic pain. Practitioner. 2009;253(1716):21-5. X-1, X-2, X-3. [pmid: 19418698].
83 Morelli SS, et al. Relaxin in endometriosis. Ann N Y Acad Sci. 2009;1160:138-9. X-1, X-2, X-3, X-4, X-5. [pmid: 19416175].
84 Lee SH, Lee BC. Electroacupuncture relieves pain in men with chronic prostatitis/chronic pelvic pain syndrome: three-arm randomized trial. Urology. 2009;73(5):1036-41. X-2, X-3, X-4. [pmid: 19394499].
85 Jedrzejczak P, et al. Effects of presacral neurectomy on pelvic pain in women with and without endometriosis. Ginekol Pol. 2009;80(3):172-8. X-3. [pmid: 19382607].
86 Tariverdian N, et al. Intraperitoneal immune cell status in infertile women with and without endometriosis. J Reprod Immunol. 2009;80(1-2):80-90. X-4. [pmid: 19375804].
87 Chlamydia screening among sexually active young female enrollees of health plans--United States, 2000-2007. MMWR Morb Mortal Wkly Rep. 2009;58(14):362-5. X-1, X-2, X-3, X-4, X-5. [pmid: 19373196].
88 Zimmermann R, et al. Extracorporeal shock wave therapy for the treatment of chronic pelvic pain syndrome in males: a randomised, double-blind, placebo-controlled study. Eur Urol. 2009;56(3):418-24. X-3, X-4, X-5. [pmid: 19372000].
89 Meltzer-Brody SE, et al. Open-label trial of lamotrigine focusing on efficacy in vulvodynia. J Reprod Med. 2009;54(3):171-8. X-3. [pmid: 19370903].
90 Donnez J, et al. Laparoscopic management of endometriomas using a combined technique of excisional (cystectomy) and ablative surgery. Fertil Steril. 2010;94(1):28-32. X-2, X-3, X-4, X-5. [pmid: 19361793].
91 Calhoun EA, et al. Primary care physician practices in the diagnosis, treatment and management of men with chronic prostatitis/chronic pelvic pain syndrome. Prostate Cancer Prostatic Dis. 2009;12(3):288-95. X-1, X-2, X-3, X-4. [pmid: 19350050].
92 Ballard K, et al. Can specific pain symptoms help in the diagnosis of endometriosis? A cohort study of women with chronic pelvic pain. Fertil Steril. 2010;94(1):20-7. X-3, X-4, X-5. [pmid: 19342028].
93 Poli-Neto OB, et al. Increased capsaicin receptor TRPV1 in the peritoneum of women with chronic pelvic pain. Clin J Pain. 2009;25(3):218-22. X-3. [pmid: 19333172].
94 Kiuchi H, et al. Increased vascular endothelial growth factor expression in patients with bladder pain syndrome/interstitial cystitis: its association with pain severity and glomerulations. BJU Int. 2009;104(6):826-31. discussion 831. X-3. [pmid: 19298410].
95 Misrai V, et al. Surgical resection for suburethral sling complications after treatment for stress urinary incontinence. J Urol. 2009;181(5):2198-202. discussion 2203. X-3, X-4. [pmid: 19296973].
96 Smith CP. Botulinum toxin in the treatment of OAB, BPH, and IC. Toxicon. 2009;54(5):639-46. X-1, X-2, X-3. [pmid: 19268490].
97 Goins WF, et al. Herpes simplex virus vector-mediated gene delivery for the treatment of lower urinary tract pain. Gene Ther. 2009;16(4):558-69. X-1, X-2, X-3, X-4, X-5. [pmid: 19242523].
98 Zhu L, et al. The epidemiological study of women with urinary incontinence and risk factors for stress urinary incontinence in China. Menopause. 2009;16(4):831-6. X-2, X-3, X-4, X-5. [pmid: 19240656].
99 Magri V, et al. Chronic prostatitis and erectile dysfunction: results from a cross-sectional study. Arch Ital Urol Androl. 2008;80(4):172-5. X-2, X-3, X-4. [pmid: 19235435].
100 Elbendary MA, El-Gamal OM, Salem KA. Analysis of risk factors for organic erectile dysfunction in Egyptian patients under the age of 40 years. J Androl. 2009;30(5):520-4. X-2, X-3, X-4. [pmid: 19234310].
101 Parazzini F, et al. Determinants of adenomyosis in women who underwent hysterectomy for benign gynecological conditions: results from a prospective multicentric study in Italy. Eur J Obstet Gynecol Reprod Biol. 2009;143(2):103-6. X-2, X-3, X-4, X-5. [pmid: 19232812].
102 Weil YA, et al. Management of persistent postpartum pelvic pain. Am J Orthop (Belle Mead NJ). 2008;37(12):621-6. X-3. [pmid: 19212572].
103 Dozois EJ, et al. Neurogenic tumors of the pelvis: clinicopathologic features and surgical outcomes using a multidisciplinary team. Ann Surg Oncol. 2009;16(4):1010-6. X-2, X-3, X-4, X-5. [pmid: 19194756].
104 Wang L, et al. Diagnosis and surgical treatment of nutcracker syndrome: a single-center experience. Urology. 2009;73(4):871-6. X-3. [pmid: 19193424].
105 Clemens JQ, Markossian T, Calhoun EA. Comparison of economic impact of chronic prostatitis/chronic pelvic pain syndrome and interstitial cystitis/painful bladder syndrome. Urology. 2009;73(4):743-6. X-2, X-3, X-4. [pmid: 19193408].
106 Shokeir T, Amr M, Abdelshaheed M. The efficacy of Implanon for the treatment of chronic pelvic pain associated with pelvic congestion: 1-year randomized controlled pilot study. Arch Gynecol Obstet. 2009;280(3):437-43. X-3. [pmid: 19190927].
107 Rechberger T, Futyma K, Bartuzi A. Total Prolift System surgery for treatment posthysterectomy vaginal vault prolapse--do we treat both anatomy and function?. Ginekol Pol. 2008;79(12):835-9. X-2, X-3, X-4. [pmid: 19175040].
108 Paterson LQ, et al. Persistent genital and pelvic pain after childbirth. J Sex Med. 2009;6(1):215-21. X-2, X-3, X-4. [pmid: 19170851].
109 de Jong MJ, et al. Surgical outcome and long-term follow-up after segmental colorectal resection in women with a complete obstruction of the rectosigmoid due to endometriosis. Dig Surg. 2009;26(1):50-5. X-3, X-4. [pmid: 19155628].
110 Kaiser A, et al. The influence of peritoneal endometriotic lesions on the generation of endometriosis-related pain and pain reduction after surgical excision. Arch Gynecol Obstet. 2009;280(3):369-73. X-3, X-4, X-5. [pmid: 19148660].
111 Shoskes DA, et al. Clinical phenotyping of patients with chronic prostatitis/chronic pelvic pain syndrome and correlation with symptom severity. Urology. 2009;73(3):538-42. discussion 542-3. X-2, X-3, X-4. [pmid: 19118880].
112 Akira S, et al. Efficacy of long-term, low-dose gonadotropin-releasing hormone agonist therapy (draw-back therapy) for adenomyosis. Med Sci Monit. 2009;15(1):CR1-4. X-3, X-4. [pmid: 19114964].
113 Sikiru L, Shmaila H, Muhammed SA. Transcutaneous electrical nerve stimulation (TENS) in the symptomatic management of chronic prostatitis/chronic pelvic pain syndrome: a placebo-control randomized trial. Int Braz J Urol. 2008;34(6):708-13. discussion 714. X-2, X-3, X-4. [pmid: 19111075].
114 Mogren IM. Physical activity and persistent low back pain and pelvic pain post partum. BMC Public Health. 2008;8:417. X-2, X-3, X-4, X-5. [pmid: 19102737].
115 Tomaskovic I, et al. Chronic prostatitis/chronic pelvic pain syndrome in males may be an autoimmune disease, potentially responsive to corticosteroid therapy. Med Hypotheses. 2009;72(3):261-2. X-1, X-2, X-3, X-4. [pmid: 19095365].
116 Nickel JC, et al. Alfuzosin and symptoms of chronic prostatitis-chronic pelvic pain syndrome. N Engl J Med. 2008;359(25):2663-73. X-2, X-3, X-4. [pmid: 19092152].
117 Podnar S. Predictive value of the penilo-cavernosus reflex. Neurourol Urodyn. 2009;28(5):390-4. X-2, X-3, X-4. [pmid: 19090584].
118 Porpora MG, et al. Pain and ovarian endometrioma recurrence after laparoscopic treatment of endometriosis: a long-term prospective study. Fertil Steril. 2010;93(3):716-21. X-2, X-3. [pmid: 19061997].
119 Honda H, et al. Serial analysis of gene expression reveals differential expression between endometriosis and normal endometrium. Possible roles for AXL and SHC1 in the pathogenesis of endometriosis. Reprod Biol Endocrinol. 2008;6:59. X-2, X-3, X-4, X-5. [pmid: 19055724].
120 Duran-Barragan S, et al. Recurrent urinary tract infections and bladder dysfunction in systemic lupus erythematosus. Lupus. 2008;17(12):1117-21. X-3. [pmid: 19029280].
121 Masheb RM, et al. A randomized clinical trial for women with vulvodynia: Cognitive-behavioral therapy vs. supportive psychotherapy. Pain. 2009;141(1-2):31-40. X-2, X-3, X-4, X-5. [pmid: 19022580].
122 Tripp DA, et al. Prevalence, symptom impact and predictors of chronic prostatitis-like symptoms in Canadian males aged 16-19 years. BJU Int. 2009;103(8):1080-4. X-2, X-3, X-4. [pmid: 19007369].
123 Taylor E, Williams C. Surgical treatment of endometriosis: location and patterns of disease at reoperation. Fertil Steril. 2010;93(1):57-61. X-3. [pmid: 19006792].
124 Warren JW, et al. Antecedent nonbladder syndromes in case-control study of interstitial cystitis/painful bladder syndrome. Urology. 2009;73(1):52-7. X-2, X-3, X-4, X-5. [pmid: 18995888].
125 Mechsner S, et al. A pilot study to evaluate the clinical relevance of endometriosis-associated nerve fibers in peritoneal endometriotic lesions. Fertil Steril. 2009;92(6):1856-61. X-2, X-3, X-4. [pmid: 18980761].
126 Barcz E, et al. A relationship between increased peritoneal leptin levels and infertility in endometriosis. Gynecol Endocrinol. 2008;24(9):526-30. X-3, X-4, X-5. [pmid: 18958774].
127 Weijenborg PT, et al. Predictors of outcome in a cohort of women with chronic pelvic pain - a follow-up study. Eur J Pain. 2009;13(7):769-75. X-3. [pmid: 18929498].
128 Hussain A, et al. Laparoscopic surgery for chronic groin pain in the general population: a prospective study. J Laparoendosc Adv Surg Tech A. 2008;18(6):809-13. X-3, X-4. [pmid: 18922058].
129 Ridgeway B, et al. Early experience with mesh excision for adverse outcomes after transvaginal mesh placement using prolapse kits. Am J Obstet Gynecol. 2008;199(6):703 e1-7. X-3. [pmid: 18845292].
130 Haugstad GK, et al. Continuing improvement of chronic pelvic pain in women after short-term Mensendieck somatocognitive therapy: results of a 1-year follow-up study. Am J Obstet Gynecol. 2008;199(6):615 e1-8. X-3. [pmid: 18845283].
131 Pisco JM, et al. Pelvic pain after uterine artery embolization: a prospective randomized study of polyvinyl alcohol particles mixed with ketoprofen versus bland polyvinyl alcohol particles. J Vasc Interv Radiol. 2008;19(11):1537-42. X-2, X-3, X-4, X-5. [pmid: 18818095].
132 Milewski L, et al. Association of leptin with inflammatory cytokines and lymphocyte subpopulations in peritoneal fluid of patients with endometriosis. J Reprod Immunol. 2008;79(1):111-7. X-3, X-4. [pmid: 18814918].
133 Rhodes KV, et al. Emergency care of urban women with sexually transmitted infections: time to address deficiencies. Sex Transm Dis. 2009;36(1):51-7. X-4. [pmid: 18813030].
134 Petrelluzzi KF, et al. Salivary cortisol concentrations, stress and quality of life in women with endometriosis and chronic pelvic pain. Stress. 2008;11(5):390-7. X-4, X-3. [pmid: 18800310].
135 Wayne PM, et al. Japanese-style acupuncture for endometriosis-related pelvic pain in adolescents and young women: results of a randomized sham-controlled trial. J Pediatr Adolesc Gynecol. 2008;21(5):247-57. X-3. [pmid: 18794019].
136 Alp BF, et al. The significance of potassium chloride sensitivity test and urinary uronic acid level in the diagnosis of chronic pelvic pain syndrome. Int Urol Nephrol. 2009;41(3):483-9. X-2, X-3, X-4. [pmid: 18792800].
137 Kastner C. Update on minimally invasive therapy for chronic prostatitis/chronic pelvic pain syndrome. Curr Urol Rep. 2008;9(4):333-8. X-2, X-3, X-4. [pmid: 18765134].
138 Nickel JC, et al. Category III chronic prostatitis/chronic pelvic pain syndrome: insights from the National Institutes of Health Chronic Prostatitis Collaborative Research Network studies. Curr Urol Rep. 2008;9(4):320-7. X-1, X-2, X-3, X-4. [pmid: 18765132].
139 St Martin L. The challenges of chronic pelvic pain. Nurs N Z. 2008;14(7):11-3. X-1, X-2, X-3, X-4, X-5. [pmid: 18751670].
140 Fenton BW, Palmieri PA, Fanning J. Receiver operating characteristic curves of symptom scores in the diagnosis of interstitial cystitis/painful bladder syndrome. J Minim Invasive Gynecol. 2008;15(5):601-4. X-2, X-3, X-4. [pmid: 18722973].
141 Landi S, et al. The influence of adenomyosis in patients laparoscopically treated for deep endometriosis. J Minim Invasive Gynecol. 2008;15(5):566-70. X-2, X-3, X-4, X-5. [pmid: 18722969].
142 Marconi M, et al. Are antisperm antibodies really associated with proven chronic inflammatory and infectious diseases of the male reproductive tract?. Eur Urol. 2009;56(4):708-15. X-2, X-3, X-4. [pmid: 18715698].
143 Bettendorf B, Shay S, Tu F. Dysmenorrhea: contemporary perspectives. Obstet Gynecol Surv. 2008;63(9):597-603. X-1, X-2, X-3, X-4. [pmid: 18713479].
144 Dhaubhadel P, Vaidya A, Choudhary P. Early detection of precursors of cervical cancer with cervical cytology and visual inspection of cervix with acetic Acid. JNMA J Nepal Med Assoc. 2008;47(170):71-6. X-3, X-4, X-5. [pmid: 18709035].
145 Clemens JQ, Brown SO, Calhoun EA. Mental health diagnoses in patients with interstitial cystitis/painful bladder syndrome and chronic prostatitis/chronic pelvic pain syndrome: a case/control study. J Urol. 2008;180(4):1378-82. X-2, X-3, X-4, X-5. [pmid: 18707716].
146 Warren JW, et al. Sites of pain from interstitial cystitis/painful bladder syndrome. J Urol. 2008;180(4):1373-7. X-2, X-3, X-4, X-5. [pmid: 18707715].
147 Conboy L, et al. A qualitative analysis of adolescents' experiences of active and sham Japanese-style acupuncture protocols administered in a clinical trial. J Altern Complement Med. 2008;14(6):699-705. X-3. [pmid: 18684076].
148 Chu PS, et al. The destruction of the lower urinary tract by ketamine abuse: a new syndrome?. BJU Int. 2008;102(11):1616-22. X-2, X-3, X-4, X-5. [pmid: 18680495].
149 Bhatia A, et al. Chronic pain in children in the UK: a survey of pain clinicians and general practitioners. Paediatr Anaesth. 2008;18(10):957-66. X-2, X-3, X-4. [pmid: 18673319].
150 Rousseau V, et al. Emergency management and conservative surgery of ovarian torsion in children: a report of 40 cases. J Pediatr Adolesc Gynecol. 2008;21(4):201-6. X-2, X-3, X-4. [pmid: 18656074].
151 Shoskes DA, et al. Clinical phenotyping in chronic prostatitis/chronic pelvic pain syndrome and interstitial cystitis: a management strategy for urologic chronic pelvic pain syndromes. Prostate Cancer Prostatic Dis. 2009;12(2):177-83. X-1, X-2, X-3, X-4. [pmid: 18645581].
152 Jonsson K, Hedelin H. Chronic abacterial prostatitis: Living with a troublesome disease affecting many aspects of life. Scand J Urol Nephrol. 2008;42(6):545-50. X-2, X-3, X-4. [pmid: 18615364].
153 Akl MN, et al. Robotic appendectomy in gynaecological surgery: technique and pathological findings. Int J Med Robot. 2008;4(3):210-3. X-3, X-4, X-5. [pmid: 18613274].
154 Breton A, Miller CM, Fisher K. Enhancing the sexual function of women living with chronic pain: a cognitive-behavioural treatment group. Pain Res Manag. 2008;13(3):219-24. X-3. [pmid: 18592058].
155 Information from your family doctor. Chronic pelvic pain: what you should know. Am Fam Physician. 2008;77(11):1544. X-1, X-2, X-3, X-4, X-5. [pmid: 18581834].
156 Bedaiwy MA, et al. Pelvic endometriosis is rarely associated with ovarian borderline tumours, cytologic and architectural atypia: a clinicopathologic study. Pathol Oncol Res. 2009;15(1):81-8. X-3, X-4. [pmid: 18575828].
157 Hsieh CL, et al. Effectiveness of ultrasound-guided aspiration and sclerotherapy with 95% ethanol for treatment of recurrent ovarian endometriomas. Fertil Steril. 2009;91(6):2709-13. X-2, X-3, X-4, X-5. [pmid: 18571165].
158 Wolfler MM, et al. Mass spectrometry and serum pattern profiling for analyzing the individual risk for endometriosis: promising insights?. Fertil Steril. 2009;91(6):2331-7. X-4. [pmid: 18555242].
159 Giberti C, et al. Transvaginal bone-anchored sling procedure: 4 years of follow-up on more than 200 consecutive patients. Urology. 2008;72(2):313-7. discussion 317. X-2, X-3, X-4, X-5. [pmid: 18554693].
160 Pham K, Guralnick ML, O'Connor RC. Unilateral versus bilateral stage I neuromodulator lead placement for the treatment of refractory voiding dysfunction. Neurourol Urodyn. 2008;27(8):779-81. X-2, X-3, X-4, X-5. [pmid: 18551562].
161 Zhou Z, et al. Detection of nanobacteria infection in type III prostatitis. Urology. 2008;71(6):1091-5. X-2, X-3, X-4. [pmid: 18538692].
162 Schnyer RN, et al. Development of protocols for randomized sham-controlled trials of complex treatment interventions: Japanese acupuncture for endometriosis-related pelvic pain. J Altern Complement Med. 2008;14(5):515-22. X-3. [pmid: 18537469].
163 Grace VM, MacBride-Stewart S. “How to say it”: women's descriptions of pelvic pain. Women Health. 2007;46(4):81-98. X-3, X-4. [pmid: 18512453].
164 Zambo L, Dekany M, Bender T. The efficacy of alum-containing ferrous thermal water in the management of chronic inflammatory gynaecological disorders--a randomized controlled study. Eur J Obstet Gynecol Reprod Biol. 2008;140(2):252-7. X-3. [pmid: 18511175].
165 Zimmermann R, et al. Extracorporeal shock-wave therapy for treating chronic pelvic pain syndrome: a feasibility study and the first clinical results. BJU Int. 2008;102(8):976-80. X-2, X-3, X-4. [pmid: 18510660].
166 Garcia-Manero M, Santana GT, Alcazar JL. Relationship between microvascular density and expression of vascular endothelial growth factor in patients with ovarian endometriosis. J Womens Health (Larchmt). 2008;17(5):777-82. X-3, X-4. [pmid: 18479230].
167 Chen J, et al. A comparison between ultrasound therapy and laser therapy for symptomatic cervical ectopy. Ultrasound Med Biol. 2008;34(11):1770-4. X-2, X-3, X-4, X-5. [pmid: 18471953].
168 Stancik I, et al. Effect of antibiotic therapy on interleukin-6 in fresh semen and postmasturbation urine samples of patients with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2008;72(2):336-9. X-2, X-3, X-4. [pmid: 18468661].
169 Roman H, et al. Why laparoscopic adhesiolysis should not be the victim of a single randomized clinical trial. Am J Obstet Gynecol. 2009;200(2):136 e1-4. X-1, X-2, X-3, X-4, X-5. [pmid: 18468569].
170 Zhu L, et al. The prevalence of and potential risk factors for female urinary incontinence in Beijing, China. Menopause. 2008;15(3):566-9. X-2, X-3, X-4, X-5. [pmid: 18467955].
171 Stegmann BJ, et al. A logistic model for the prediction of endometriosis. Fertil Steril. 2009;91(1):51-5. X-4. [pmid: 18462722].
172 Nevin RL, et al. Cost and effectiveness of Chlamydia screening among male military recruits: Markov modeling of complications averted through notification of prior female partners. Sex Transm Dis. 2008;35(8):705-13. X-2, X-3, X-4. [pmid: 18461015].
173 Taylor BC, et al. Excessive antibiotic use in men with prostatitis. Am J Med. 2008;121(5):444-9. X-2, X-3, X-4. [pmid: 18456041].
174 Haggerty CL, et al. Failure of cefoxitin and doxycycline to eradicate endometrial Mycoplasma genitalium and the consequence for clinical cure of pelvic inflammatory disease. Sex Transm Infect. 2008;84(5):338-42. X-2, X-3, X-4, X-5. [pmid: 18445635].
175 Brown CS, et al. Citalopram in the treatment of women with chronic pelvic pain: an open-label trial. J Reprod Med. 2008;53(3):191-5. X-3. [pmid: 18441724].
176 Florido J, Perez-Lucas R, Navarrete L. Sexual behavior and findings on laparoscopy or laparotomy in women with severe chronic pelvic pain. Eur J Obstet Gynecol Reprod Biol. 2008;139(2):233-6. X-3. [pmid: 18403089].
177 Taylor GJ. The challenge of chronic pain: a psychoanalytic approach. J Am Acad Psychoanal Dyn Psychiatry. 2008;36(1):49-68. X-1, X-2, X-3, X-4. [pmid: 18399746].
178 Marszalek M, et al. Chronic pelvic pain and lower urinary tract symptoms in both sexes: analysis of 2749 participants of an urban health screening project. Eur Urol. 2009;55(2):499-507. X-3, X-4. [pmid: 18395963].
179 Dienstmann R, et al. Palliative percutaneous nephrostomy in recurrent cervical cancer: a retrospective analysis of 50 consecutive cases. J Pain Symptom Manage. 2008;36(2):185-90. X-2, X-3, X-4, X-5. [pmid: 18395404].
180 Peters KM, Carrico DJ, Diokno AC. Characterization of a clinical cohort of 87 women with interstitial cystitis/painful bladder syndrome. Urology. 2008;71(4):634-40. X-2, X-3, X-4, X-5. [pmid: 18387392].
181 Larsen MS, et al. Quantifying mast cells in bladder pain syndrome by immunohistochemical analysis. BJU Int. 2008;102(2):204-7. discussion 207. X-2, X-3, X-4, X-5. [pmid: 18384636].
182 Ye ZQ, et al. Tamsulosin treatment of chronic non-bacterial prostatitis. J Int Med Res. 2008;36(2):244-52. X-2, X-3, X-4. [pmid: 18380933].
183 Ejike CE, Ezeanyika LU. Prevalence of chronic prostatitis symptoms in a randomly surveyed adult population of urban-community-dwelling Nigerian males. Int J Urol. 2008;15(4):340-3. X-2, X-3, X-4. [pmid: 18380824].
184 Jeong CW, et al. Treatment for chronic prostatitis/chronic pelvic pain syndrome: levofloxacin, doxazosin and their combination. Urol Int. 2008;80(2):157-61. X-2, X-3, X-4. [pmid: 18362485].
185 Jelovsek JE, Walters MD, Barber MD. Psychosocial impact of chronic vulvovagina conditions. J Reprod Med. 2008;53(2):75-82. X-2, X-3, X-4, X-5. [pmid: 18357797].
186 Manderson L, Warren N, Markovic M. Circuit breaking: pathways of treatment seeking for women with endometriosis in Australia. Qual Health Res. 2008;18(4):522-34. X-3, X-4, X-5. [pmid: 18354050].
187 Desireddi NV, et al. Monocyte chemoattractant protein-1 and macrophage inflammatory protein-1alpha as possible biomarkers for the chronic pelvic pain syndrome. J Urol. 2008;179(5):1857-61. discussion 1861-2. X-2, X-3, X-4. [pmid: 18353390].
188 Pitts M, et al. Prevalence and correlates of three types of pelvic pain in a nationally representative sample of Australian men. J Sex Med. 2008;5(5):1223-9. X-2, X-3, X-4. [pmid: 18331265].
189 Tropeano G, et al. Ovarian vein incompetence: a potential cause of chronic pelvic pain in women. Eur J Obstet Gynecol Reprod Biol. 2008;139(2):215-21. X-3. [pmid: 18313828].
190 Tu FF, et al. Physical therapy evaluation of patients with chronic pelvic pain: a controlled study. Am J Obstet Gynecol. 2008;198(3):272 e1-7. X-3, X-4. [pmid: 18313447].
191 Kazanegra R, et al. Diagnosis of stage I endometriosis: comparing visual inspection to histologic biopsy specimen. J Minim Invasive Gynecol. 2008;15(2):176-80. X-3, X-4, X-5. [pmid: 18312987].
192 Dimitrakov J, et al. Adrenocortical hormone abnormalities in men with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2008;71(2):261-6. X-2, X-3, X-4. [pmid: 18308097].
193 Nickel JC, Mullins C, Tripp DA. Development of an evidence-based cognitive behavioral treatment program for men with chronic prostatitis/chronic pelvic pain syndrome. World J Urol. 2008;26(2):167-72. X-2, X-3, X-4. [pmid: 18293000].
194 Wie HJ, et al. Is incidental appendectomy necessary in women with ovarian endometrioma?. Aust N Z J Obstet Gynaecol. 2008;48(1):107-11. X-3, X-4. [pmid: 18275581].
195 Sharma JB, et al. Laparoscopic findings in female genital tuberculosis. Arch Gynecol Obstet. 2008;278(4):359-64. X-2, X-3, X-4, X-5. [pmid: 18273629].
196 Jenkins TR, Liu CY, White J. Does response to hormonal therapy predict presence or absence of endometriosis?. J Minim Invasive Gynecol. 2008;15(1):82-6. X-3, X-4, X-5. [pmid: 18262150].
197 Cheong Y, et al. Laparoscopic surgery for endometriosis: How often do we need to re-operate?. J Obstet Gynaecol. 2008;28(1):82-5. X-2, X-3. [pmid: 18259906].
198 Weiss G, et al. Adenomyosis a variant, not a disease? Evidence from hysterectomized menopausal women in the Study of Women's Health Across the Nation (SWAN). Fertil Steril. 2009;91(1):201-6. X-4. [pmid: 18243177].
199 Lee SW, et al. Adverse impact of sexual dysfunction in chronic prostatitis/chronic pelvic pain syndrome. Urology. 2008;71(1):79-84. X-2, X-3, X-4. [pmid: 18242370].
200 Hornick L, Slocumb JC. Treating chronic pelvic pain. Focus on pain triggers and neurogenic inflammation. Adv Nurse Pract. 2008;16(2):44-53. quiz 54. X-1, X-2, X-3, X-4, X-5. [pmid: 19999446].
201 Aubin S, et al. The association between sexual function, pain, and psychological adaptation of men diagnosed with chronic pelvic pain syndrome type III. J Sex Med. 2008;5(3):657-67. X-2, X-3, X-4. [pmid: 18208504].
202 Anderson RU, et al. Psychometric profiles and hypothalamic-pituitary-adrenal axis function in men with chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2008;179(3):956-60. X-2, X-3, X-4. [pmid: 18207189].
203 Lee SW, et al. Acupuncture versus sham acupuncture for chronic prostatitis/chronic pelvic pain. Am J Med. 2008;121(1):79 e1-7. X-2, X-3, X-4. [pmid: 18187077].
204 Berman SM, et al. Reduced brainstem inhibition during anticipated pelvic visceral pain correlates with enhanced brain response to the visceral stimulus in women with irritable bowel syndrome. J Neurosci. 2008;28(2):349-59. X-2, X-3, X-4. [pmid: 18184777].
205 Gandini R, et al. Transcatheter foam sclerotherapy of symptomatic female varicocele with sodium-tetradecyl-sulfate foam. Cardiovasc Intervent Radiol. 2008;31(4):778-84. X-3. [pmid: 18172712].
206 Trautmann GM, et al. Do short-term markers of treatment efficacy predict long-term sequelae of pelvic inflammatory disease?. Am J Obstet Gynecol. 2008;198(1):30 e1-7. X-4. [pmid: 18166300].
207 Schaeffer AJ. Epidemiology and evaluation of chronic pelvic pain syndrome in men. Int J Antimicrob Agents. Suppl 1. 2008;31:S108-11. X-1, X-2, X-3, X-4. [pmid: 18164597].
208 Pandza H, et al. Laparoscopic treatment of lower abdominal pain related to chronic appendicitis. Med Arh. 2008;62(5-6):268-70. X-2, X-3, X-4, X-5. [pmid: 19469267].
209 Weidner W, Anderson RU. Evaluation of acute and chronic bacterial prostatitis and diagnostic management of chronic prostatitis/chronic pelvic pain syndrome with special reference to infection/inflammation. Int J Antimicrob Agents. Suppl 1. 2008;31:S91-5. X-1, X-2, X-3, X-4. [pmid: 18162376].
210 Wingenfeld K, et al. HPA axis reactivity and lymphocyte glucocorticoid sensitivity in fibromyalgia syndrome and chronic pelvic pain. Psychosom Med. 2008;70(1):65-72. X-3, X-4. [pmid: 18158367].
211 Petta CA, et al. Current practice in the management of symptoms of endometriosis: a survey of Brazilian gynecologists. Rev Assoc Med Bras. 2007;53(6):525-9. X-2, X-3, X-4, X-5. [pmid: 18157368].
212 Quinn M. Injuries to the levator ani in unexplained, chronic pelvic pain. J Obstet Gynaecol. 2007;27(8):828-31. X-3, X-4. [pmid: 18097905].
213 Shoskes DA, et al. Muscle tenderness in men with chronic prostatitis/chronic pelvic pain syndrome: the chronic prostatitis cohort study. J Urol. 2008;179(2):556-60. X-2, X-3, X-4. [pmid: 18082223].
214 Kessler TM, et al. Safety of prolonged sacral neuromodulation tined lead testing. Curr Med Res Opin. 2008;24(2):343-7. X-3. [pmid: 18073008].
215 Denny E, Mann CH. Endometriosis and the primary care consultation. Eur J Obstet Gynecol Reprod Biol. 2008;139(1):111-5. X-3, X-4. [pmid: 18068292].
216 Tu FF, et al. Comparative measurement of pelvic floor pain sensitivity in chronic pelvic pain. Obstet Gynecol. 2007;110(6):1244-8. X-3, X-4. [pmid: 18055716].
217 Cheong Y, Stones RW. Doctors and the chronic pelvic pain patient. Minerva Ginecol. 2007;59(6):613-8. X-1, X-2, X-3, X-4. [pmid: 18043575].
218 Tettambel MA. Using integrative therapies to treat women with chronic pelvic pain. J Am Osteopath Assoc. 2007;107(10 Suppl 6):ES17-20. X-1, X-2, X-3. [pmid: 17986673].
219 Mogren I. Perceived health six months after delivery in women who have experienced low back pain and pelvic pain during pregnancy. Scand J Caring Sci. 2007;21(4):447-55. X-2, X-3, X-4, X-5. [pmid: 18036007].
220 Smith KJ, et al. Quality of life utilities for pelvic inflammatory disease health states. Sex Transm Dis. 2008;35(3):307-11. X-2, X-4. [pmid: 18032995].
221 Mitra R, Cheung L, Perry P. Efficacy of fluoroscopically guided steroid injections in the management of coccydynia. Pain Physician. 2007;10(6):775-8. X-3. [pmid: 17987101].
222 Schultz DM. Inferior hypogastric plexus blockade: a transsacral approach. Pain Physician. 2007;10(6):757-63. X-3. [pmid: 17987098].
223 Flores I, et al. Self-reported prevalence of endometriosis and its symptoms among Puerto Rican women. Int J Gynaecol Obstet. 2008;100(3):257-61. X-2, X-3, X-4, X-5. [pmid: 17976623].
224 Hindson B, Turner S, Do V. Palliative radiation therapy for localized prostate symptoms in hormone refractory prostate cancer. Australas Radiol. 2007;51(6):584-8. X-2, X-3, X-4. [pmid: 17958697].
225 Nickel JC. Treatment of chronic prostatitis/chronic pelvic pain syndrome. Int J Antimicrob Agents. Suppl 1. 2008;31:S112-6. X-1, X-2, X-3, X-4. [pmid: 17954024].
226 Walz J, et al. Impact of chronic prostatitis-like symptoms on the quality of life in a large group of men. BJU Int. 2007;100(6):1307-11. X-2, X-3, X-4. [pmid: 17941922].
227 Bartoletti R, et al. Prevalence, incidence estimation, risk factors and characterization of chronic prostatitis/chronic pelvic pain syndrome in urological hospital outpatients in Italy: results of a multicenter case-control observational study. J Urol. 2007;178(6):2411-5. discussion 2415. X-2, X-3, X-4. [pmid: 17937946].
228 Mettler L, Alhujeily M. Role of laparoscopy in identifying the clinical significance and cause of adhesions and chronic pelvic pain: a retrospective review at the Kiel School of Gynecological Endoscopy. JSLS. 2007;11(3):303-8. X-2, X-3, X-4, X-5. [pmid: 17931511].
229 Zabihi N, et al. Short-term results of bilateral S2-S4 sacral neuromodulation for the treatment of refractory interstitial cystitis, painful bladder syndrome, and chronic pelvic pain. Int Urogynecol J Pelvic Floor Dysfunct. 2008;19(4):553-7. X-3. [pmid: 17925994].
230 Nickel JC, et al. Psychosocial variables affect the quality of life of men diagnosed with chronic prostatitis/chronic pelvic pain syndrome. BJU Int. 2008;101(1):59-64. X-2, X-3, X-4. [pmid: 17924985].
231 Deligdisch L, et al. Stage I ovarian carcinoma: different clinical pathologic patterns. Fertil Steril. 2007;88(4):906-10. X-2, X-3, X-4, X-5. [pmid: 17920404].
232 Sievert KD, et al. Subcutaneous tunneling of the temporary testing electrode significantly improves the success rate of subchronic sacral nerve modulation (SNM). World J Urol. 2007;25(6):607-12. X-3. [pmid: 17912530].
233 Berger RE, et al. Pelvic tenderness is not limited to the prostate in chronic prostatitis/chronic pelvic pain syndrome (CPPS) type IIIA and IIIB: comparison of men with and without CP/CPPS. BMC Urol. 2007;7:17. X-2, X-3, X-4. [pmid: 17908331].
234 Wynn ML, Chang S, Peipins LA. Temporal patterns of conditions and symptoms potentially associated with ovarian cancer. J Womens Health (Larchmt). 2007;16(7):971-86. X-2, X-3, X-4. [pmid: 17903074].
235 Verit FF, Verit A. Validation of the female sexual function index in women with chronic pelvic pain. J Sex Med. 2007;4(6):1635-41. X-4. [pmid: 17888066].
236 Toshniwal GR, Dureja GP, Prashanth SM. Transsacrococcygeal approach to ganglion impar block for management of chronic perineal pain: a prospective observational study. Pain Physician. 2007;10(5):661-6. X-3, X-4. [pmid: 17876362].
237 Barry MJ, et al. Overlap of different urological symptom complexes in a racially and ethnically diverse, community-based population of men and women. BJU Int. 2008;101(1):45-51. X-2, X-3, X-4, X-5. [pmid: 17868419].
238 Hedelin H, Jonsson K. Chronic abacterial prostatitis and cold exposure: an explorative study. Scand J Urol Nephrol. 2007;41(5):430-5. X-2, X-3, X-4. [pmid: 17853032].
239 Hedelin H, Jonsson K. Chronic prostatitis/chronic pelvic pain syndrome: symptoms are aggravated by cold and become less distressing with age and time. Scand J Urol Nephrol. 2007;41(6):516-20. X-2, X-3, X-4. [pmid: 17853027].
240 Seng JS, et al. Service use data analysis of pre-pregnancy psychiatric and somatic diagnoses in women with hyperemesis gravidarum. J Psychosom Obstet Gynaecol. 2007;28(4):209-17. X-4. [pmid: 17852658].
241 Kulovac B, et al. Management of chronic nonbacterial prostatitis/chronic pelvic pain syndrome. Bosn J Basic Med Sci. 2007;7(3):245-9. X-2, X-3, X-4. [pmid: 17848151].
242 Randall GW, et al. Serum antiendometrial antibodies and diagnosis of endometriosis. Am J Reprod Immunol. 2007;58(4):374-82. X-3, X-4, X-5. [pmid: 17845208].
243 Shoskes DA, et al. Incidence and significance of prostatic stones in men with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2007;70(2):235-8. X-2, X-3, X-4. [pmid: 17826477].
244 Hu JC, et al. The association of abuse and symptoms suggestive of chronic prostatitis/chronic pelvic pain syndrome: results from the Boston Area Community Health survey. J Gen Intern Med. 2007;22(11):1532-7. X-2, X-3, X-4. [pmid: 17763912].
245 Athanasiou S, et al. Clinical and urodynamic parameters associated with history of urinary tract infections in women. Acta Obstet Gynecol Scand. 2007;86(9):1130-5. X-2, X-3, X-4, X-5. [pmid: 17712657].
246 Brewer ME, et al. Validity of Pelvic Pain, Urgency, and Frequency questionnaire in patients with interstitial cystitis/painful bladder syndrome. Urology. 2007;70(4):646-9. X-2, X-3, X-4, X-5. [pmid: 17707887].
247 Clemens JQ, et al. Overlap of voiding symptoms, storage symptoms and pain in men and women. J Urol. 2007;178(4 Pt 1):1354-8. discussion 1358. X-2, X-3, X-4, X-5. [pmid: 17706719].
248 Fedele L, et al. Evaluation of a new questionnaire for the presurgical diagnosis of bladder endometriosis. Hum Reprod. 2007;22(10):2698-701. X-3, X-4, X-5. [pmid: 17704501].
249 Zeng Y, et al. Uroplakin III-delta4 messenger RNA as a promising marker to identify nonulcerative interstitial cystitis. J Urol. 2007;178(4 Pt 1):1322-7. discussion 1327. X-2, X-3, X-4. [pmid: 17698128].
250 Magri V, et al. Reduction of PSA values by combination pharmacological therapy in patients with chronic prostatitis: implications for prostate cancer detection. Arch Ital Urol Androl. 2007;79(2):84-92. X-2, X-3, X-4. [pmid: 17695414].
251 Trinchieri A, et al. Prevalence of sexual dysfunction in men with chronic prostatitis/chronic pelvic pain syndrome. Arch Ital Urol Androl. 2007;79(2):67-70. X-2, X-3, X-4. [pmid: 17695411].
252 Mazzoli S, et al. The AISPEP (Associazione Italiana Sindromi Pelvico Prostatiche) chronic prostatitis questionnaire (AISPEP-Q). focus on the disease: anamnestic data, life activities, symptoms, sexual habits, quality of life and knowledge about prostatitis from 93 questions answered on the Internet. Arch Ital Urol Androl. 2007;79(2):58-66. X-1, X-2, X-3, X-4. [pmid: 17695410].
253 Bonilla DJ, et al. Uterine weight as a predictor of morbidity after a benign abdominal and total laparoscopic hysterectomy. J Reprod Med. 2007;52(6):490-8. X-2, X-3, X-4, X-5. [pmid: 17694966].
254 Kothari S. Neuromodulatory approaches to chronic pelvic pain and coccygodynia. Acta Neurochir Suppl. 2007;97(Pt 1):365-71. X-1, X-2, X-3, X-4, X-5. [pmid: 17691398].
255 Weijenborg PT, et al. Clinical course of chronic pelvic pain in women. Pain. Suppl 1. 2007;132:S117-23. X-3, X-4. [pmid: 17689866].
256 Hassan AA, et al. Evaluation of intravesical potassium sensitivity test and bladder biopsy in patients with chronic prostatitis/chronic pelvic pain syndrome. Int J Urol. 2007;14(8):738-42. X-2, X-3, X-4. [pmid: 17681066].
257 Aasvang EK, Mohl B, Kehlet H. Ejaculatory pain: a specific postherniotomy pain syndrome?. Anesthesiology. 2007;107(2):298-304. X-2, X-3, X-4. [pmid: 17667575].
258 Stegmann BJ, et al. Using location, color, size, and depth to characterize and identify endometriosis lesions in a cohort of 133 women. Fertil Steril. 2008;89(6):1632-6. X-4. [pmid: 17662280].
259 Nickel JC, et al. Examination of the relationship between symptoms of prostatitis and histological inflammation: baseline data from the REDUCE chemoprevention trial. J Urol. 2007;178(3 Pt 1):896-900. discussion 900-1. X-2, X-3, X-4. [pmid: 17632164].
260 Cicinelli E, et al. Predictive factors for pain experienced at office fluid minihysteroscopy. J Minim Invasive Gynecol. 2007;14(4):485-8. X-2, X-3, X-4, X-5. [pmid: 17630168].
261 Simsek M, Burak F, Taskin O. Effects of micronized purified flavonoid fraction (Daflon) on pelvic pain in women with laparoscopically diagnosed pelvic congestion syndrome: a randomized crossover trial. Clin Exp Obstet Gynecol. 2007;34(2):96-8. X-3. [pmid: 17629162].
262 Kim J, et al. p53 mediates interstitial cystitis antiproliferative factor (APF)-induced growth inhibition of human urothelial cells. FEBS Lett. 2007;581(20):3795-9. X-2, X-3, X-4, X-5. [pmid: 17628545].
263 Denny E, Mann CH. Endometriosis-associated dyspareunia: the impact on women's lives. J Fam Plann Reprod Health Care. 2007;33(3):189-93. X-3. [pmid: 17609078].
264 Keltz MD, Gera PS, Olive DL. Prospective randomized trial of right-sided paracolic adhesiolysis for chronic pelvic pain. JSLS. 2006;10(4):443-6. X-3. [pmid: 17575754].
265 Guerriero S, et al. “Tenderness-guided” transvaginal ultrasonography: a new method for the detection of deep endometriosis in patients with chronic pelvic pain. Fertil Steril. 2007;88(5):1293-7. X-2, X-3, X-4, X-5. [pmid: 17548084].
266 Razzi S, et al. Efficacy of vaginal danazol treatment in women with recurrent deeply infiltrating endometriosis. Fertil Steril. 2007;88(4):789-94. X-3. [pmid: 17544421].
267 Thompson DG. Severe chronic abdominal pain in the absence of adhesions. Best Pract Res Clin Gastroenterol. 2007;21(3):465-72. X-1, X-2, X-3. [pmid: 17544111].
268 Peters AA, Van den Tillaart SA. The difficult patient in gastroenterology: chronic pelvic pain, adhesions, and sub occlusive episodes. Best Pract Res Clin Gastroenterol. 2007;21(3):445-63. X-1, X-2, X-3, X-4, X-5. [pmid: 17544110].
269 Liu X, et al. Patterns of and risk factors for recurrence in women with ovarian endometriomas. Obstet Gynecol. 2007;109(6):1411-20. X-2, X-3, X-4, X-5. [pmid: 17540815].
270 Daniels NA, et al. Association between past urinary tract infections and current symptoms suggestive of chronic prostatitis/chronic pelvic pain syndrome. J Natl Med Assoc. 2007;99(5):509-16. X-2, X-3, X-4. [pmid: 17534008].
271 Yilmaz U, et al. Autonomic nervous system changes in men with chronic pelvic pain syndrome. J Urol. 2007;177(6):2170-4. discussion 2174. X-2, X-3, X-4. [pmid: 17509311].
272 Evans DT, Jaleel H, Keefe A. Retrospective review of clinical practice in chronic pelvic pain syndrome i.e. category III chronic prostatitis at two hospital sites over five years 2000-2005 (an audit). Int J STD AIDS. 2007;18(4):276-80. X-2, X-3, X-4. [pmid: 17509180].
273 Seracchioli R, et al. Surgical outcome and long-term follow up after laparoscopic rectosigmoid resection in women with deep infiltrating endometriosis. BJOG. 2007;114(7):889-95. X-3. [pmid: 17501958].
274 Slawik S, et al. Laparoscopic ventral rectopexy, posterior colporrhaphy and vaginal sacrocolpopexy for the treatment of recto-genital prolapse and mechanical outlet obstruction. Colorectal Dis. 2008;10(2):138-43. X-2, X-3, X-4. [pmid: 17498206].
275 Chang CY, et al. Comparison of a new modified laparoscopic presacral neurectomy and conventional laparoscopic presacral neurectomy in the treatment of midline dysmenorrhea. Int J Gynaecol Obstet. 2007;99(1):28-32. X-2, X-3, X-4, X-5. [pmid: 17481632].
276 Strzempko Butt F, Chesla C. Relational patterns of couples living with chronic pelvic pain from endometriosis. Qual Health Res. 2007;17(5):571-85. X-3, X-4. [pmid: 17478641].
277 Guney M, et al. Intrauterine lidocaine infusion for pain relief during saline solution infusion sonohysterography: a randomized, controlled trial. J Minim Invasive Gynecol. 2007;14(3):304-10. X-2, X-3, X-4, X-5. [pmid: 17478360].
278 Kho RM, Magrina JF, Magtibay PM. Pathologic findings and outcomes of a minimally invasive approach to ovarian remnant syndrome. Fertil Steril. 2007;87(5):1005-9. X-3. [pmid: 17478171].
279 Kwon SH, et al. Transcatheter ovarian vein embolization using coils for the treatment of pelvic congestion syndrome. Cardiovasc Intervent Radiol. 2007;30(4):655-61. X-3. [pmid: 17468903].
280 Brandsborg B, et al. Risk factors for chronic pain after hysterectomy: a nationwide questionnaire and database study. Anesthesiology. 2007;106(5):1003-12. X-2, X-3. [pmid: 17457133].
281 McGowan L, et al. How do you explain a pain that can't be seen?: the narratives of women with chronic pelvic pain and their disengagement with the diagnostic cycle. Br J Health Psychol. 2007;12(Pt 2):261-74. X-3. [pmid: 17456285].
282 Smith KB, et al. Predictors of sexual and relationship functioning in couples with Chronic Prostatitis/Chronic Pelvic Pain Syndrome. J Sex Med. 2007;4(3):734-44. X-2, X-3, X-4. [pmid: 17451490].
283 Marszalek M, et al. Symptoms suggestive of chronic pelvic pain syndrome in an urban population: prevalence and associations with lower urinary tract symptoms and erectile function. J Urol. 2007;177(5):1815-9. X-2, X-3, X-4. [pmid: 17437827].
284 Jeng CJ, et al. Laparoscopy-guided myometrial biopsy in the definite diagnosis of diffuse adenomyosis. Hum Reprod. 2007;22(7):2016-9. X-2, X-3, X-4, X-5. [pmid: 17428879].
285 Wong GT, et al. Persistent pain in patients following scoliosis surgery. Eur Spine J. 2007;16(10):1551-6. X-2, X-3, X-4. [pmid: 17410382].
286 Mirkin D, Murphy-Barron C, Iwasaki K. Actuarial analysis of private payer administrative claims data for women with endometriosis. J Manag Care Pharm. 2007;13(3):262-72. X-2. [pmid: 17407392].
287 Meltzer-Brody S, et al. Trauma and posttraumatic stress disorder in women with chronic pelvic pain. Obstet Gynecol. 2007;109(4):902-8. X-3, X-4, X-5. [pmid: 17400852].
288 McKinlay JB, Link CL. Measuring the urologic iceberg: design and implementation of the Boston Area Community Health (BACH) Survey. Eur Urol. 2007;52(2):389-96. X-1, X-2, X-3, X-4. [pmid: 17383808].
289 Learman LA, et al. Predictors of hysterectomy in women with common pelvic problems: a uterine survival analysis. J Am Coll Surg. 2007;204(4):633-41. X-2, X-3, X-4, X-5. [pmid: 17382223].
290 Frenna V, et al. Laparoscopic management of ureteral endometriosis: our experience. J Minim Invasive Gynecol. 2007;14(2):169-71. X-2, X-3, X-4, X-5. [pmid: 17368251].
291 Pearce C, Curtis M. A multidisciplinary approach to self care in chronic pelvic pain. Br J Nurs. 2007;16(2):82-5. X-1, X-2, X-3. [pmid: 17353816].
292 Acien P, et al. Aromatase expression in endometriotic tissues and its relationship to clinical and analytical findings. Fertil Steril. 2007;88(1):32-8. X-2, X-3, X-4, X-5. [pmid: 17336977].
293 Alcazar JL, Garcia-Manero M. Ovarian endometrioma vascularization in women with pelvic pain. Fertil Steril. 2007;87(6):1271-6. X-2, X-3, X-4, X-5. [pmid: 17336965].
294 Skaggs CD, et al. Back and pelvic pain in an underserved United States pregnant population: a preliminary descriptive survey. J Manipulative Physiol Ther. 2007;30(2):130-4. X-2, X-3, X-4. [pmid: 17320734].
295 Bates SM, et al. A prospective, randomized, double-blind trial to evaluate the role of a short reducing course of oral corticosteroid therapy in the treatment of chronic prostatitis/chronic pelvic pain syndrome. BJU Int. 2007;99(2):355-9. X-2, X-3, X-4. [pmid: 17313424].
296 Garcia-Manero M, Alcazar JL, Toledo G. Vascular endothelial growth factor (VEGF) and ovarian endometriosis: correlation between VEGF serum levels, VEGF cellular expression, and pelvic pain. Fertil Steril. 2007;88(2):513-5. X-2, X-3, X-4, X-5. [pmid: 17296185].
297 Fenton BW. Limbic associated pelvic pain: a hypothesis to explain the diagnostic relationships and features of patients with chronic pelvic pain. Med Hypotheses. 2007;69(2):282-6. X-1, X-2, X-3. [pmid: 17292560].
298 Gomes MK, et al. The levonorgestrel-releasing intrauterine system and endometriosis staging. Fertil Steril. 2007;87(5):1231-4. X-2, X-3, X-4, X-5. [pmid: 17292364].
299 Brinkert W, et al. Dysmenorrhoea is associated with hypersensitivity in the sigmoid colon and rectum. Pain. Suppl 1. 2007;132:S46-51. X-2, X-3, X-4. [pmid: 17257758].
300 Grassi R, et al. Coccygeal movement: assessment with dynamic MRI. Eur J Radiol. 2007;61(3):473-9. X-2, X-3, X-4, X-5. [pmid: 17224255].
301 Alborzi S, et al. Pentoxifylline therapy after laparoscopic surgery for different stages of endometriosis: a prospective, double-blind, randomized, placebo-controlled study. J Minim Invasive Gynecol. 2007;14(1):54-8. X-3, X-4, X-5. [pmid: 17218230].
302 Langford CF, Udvari Nagy S, Ghoniem GM. Levator ani trigger point injections: An underutilized treatment for chronic pelvic pain. Neurourol Urodyn. 2007;26(1):59-62. X-3. [pmid: 17195176].
303 Kim SW, Paick JS, Ku JH. Percutaneous posterior tibial nerve stimulation in patients with chronic pelvic pain: a preliminary study. Urol Int. 2007;78(1):58-62. X-3. [pmid: 17192734].
304 Smith KB, et al. Sexual and relationship functioning in men with chronic prostatitis/chronic pelvic pain syndrome and their partners. Arch Sex Behav. 2007;36(2):301-11. X-2, X-3, X-4. [pmid: 17186130].
305 Yousefi S, et al. Repeat uterine artery embolization: indications and technical findings. J Vasc Interv Radiol. 2006;17(12):1923-9. X-3. [pmid: 17185687].
306 Loverro G, et al. A randomized study comparing triptorelin or expectant management following conservative laparoscopic surgery for symptomatic stage III-IV endometriosis. Eur J Obstet Gynecol Reprod Biol. 2008;136(2):194-8. X-3. [pmid: 17178185].
307 Turk S, et al. Coryneform bacteria in semen of chronic prostatitis patients. Int J Androl. 2007;30(2):123-8. X-2, X-3, X-4. [pmid: 17163953].
308 Giubilei G, et al. Physical activity of men with chronic prostatitis/chronic pelvic pain syndrome not satisfied with conventional treatments--could it represent a valid option? The physical activity and male pelvic pain trial: a double-blind, randomized study. J Urol. 2007;177(1):159-65. X-2, X-3, X-4. [pmid: 17162029].
309 Lee SW, et al. Demographic and clinical characteristics of chronic prostatitis: prospective comparison of the University of Sciences Malaysia Cohort with the United States National Institutes of Health Cohort. J Urol. 2007;177(1):153-7. discussion 158. X-2, X-3, X-4. [pmid: 17162027].
310 Scholbach T. From the nutcracker-phenomenon of the left renal vein to the midline congestion syndrome as a cause of migraine, headache, back and abdominal pain and functional disorders of pelvic organs. Med Hypotheses. 2007;68(6):1318-27. X-2, X-3, X-4, X-5. [pmid: 17161550].
311 Grace VM, MacBride-Stewart S. ‘Women get this’: gendered meanings of chronic pelvic pain. Health (London). 2007;11(1):47-67. X-3, X-4. [pmid: 17158831].
312 Weijenborg PT, ter Kuile MM, Jansen FW. Intraobserver and interobserver reliability of videotaped laparoscopy evaluations for endometriosis and adhesions. Fertil Steril. 2007;87(2):373-80. X-4. [pmid: 17141769].
313 Kessler TM, et al. Sacral neuromodulation for refractory lower urinary tract dysfunction: results of a nationwide registry in Switzerland. Eur Urol. 2007;51(5):1357-63. X-3. [pmid: 17113216].
314 Mazzoli S, et al. Interleukin 8 and anti-chlamydia trachomatis mucosal IgA as urogenital immunologic markers in patients with C. trachomatis prostatic infection. Eur Urol. 2007;51(5):1385-93. X-2, X-3, X-4. [pmid: 17107749].
315 Kang SB, et al. Impact of diagnostic laparoscopy on the management of chronic pelvic pain. Surg Endosc. 2007;21(6):916-9. X-3, X-4, X-5. [pmid: 17103271].
316 O'Callaghan D. Endometriosis--an update. Aust Fam Physician. 2006;35(11):864-7. X-1, X-2, X-3. [pmid: 17099804].
317 Tugcu V, et al. A placebo-controlled comparison of the efficiency of triple- and monotherapy in category III B chronic pelvic pain syndrome (CPPS). Eur Urol. 2007;51(4):1113-7. discussion 1118. X-2, X-3, X-4, X-5. [pmid: 17084960].
318 Haugstad GK, et al. Posture, movement patterns, and body awareness in women with chronic pelvic pain. J Psychosom Res. 2006;61(5):637-44. X-3, X-4, X-5. [pmid: 17084141].
319 Sutherland SE, et al. Sacral nerve stimulation for voiding dysfunction: One institution's 11-year experience. Neurourol Urodyn. 2007;26(1):19-28. discussion 36. X-2, X-3, X-4, X-5. [pmid: 17078071].
320 Ballard K, Lowton K, Wright J. What's the delay? A qualitative study of women's experiences of reaching a diagnosis of endometriosis. Fertil Steril. 2006;86(5):1296-301. X-3, X-4. [pmid: 17070183].
321 Schaeffer AJ. Clinical practice. Chronic prostatitis and the chronic pelvic pain syndrome. N Engl J Med. 2006;355(16):1690-8. X-1, X-2, X-3, X-4. [pmid: 17050893].
322 Takeyama K, et al. The 6-fluoro-8-methoxy quinolone gatifloxacin down-regulates interleukin-8 production in prostate cell line PC-3. Antimicrob Agents Chemother. 2007;51(1):162-8. X-2, X-3, X-4. [pmid: 17043111].
323 Wright J Jr, et al. Pelvic pain presenting in a combat environment. Mil Med. 2006;171(9):841-3. X-2, X-3, X-4, X-5. [pmid: 17036603].
324 Stanford E, McMurphy C. There is a low incidence of recurrent bacteriuria in painful bladder syndrome/interstitial cystitis patients followed longitudinally. Int Urogynecol J Pelvic Floor Dysfunct. 2007;18(5):551-4. X-2, X-4. [pmid: 17036170].
325 El-Nashaar A, et al. Validity and reliability of the arabic version of the National Institutes of Health Chronic Prostatitis Symptom Index. Urol Int. 2006;77(3):227-31. X-2, X-3, X-4. [pmid: 17033210].
326 Tripp DA, et al. Catastrophizing and pain-contingent rest predict patient adjustment in men with chronic prostatitis/chronic pelvic pain syndrome. J Pain. 2006;7(10):697-708. X-2, X-3, X-4. [pmid: 17018330].
327 Kunishima Y, et al. Prevalence of prostatitis-like symptoms in Japanese men: Population-based study in a town in Hokkaido. Int J Urol. 2006;13(10):1286-9. X-2, X-3, X-4. [pmid: 17010006].
328 Blandford JM, Gift TL. Productivity losses attributable to untreated chlamydial infection and associated pelvic inflammatory disease in reproductive-aged women. Sex Transm Dis. 2006;33(10 Suppl):S117-21. X-2, X-3, X-4, X-5. [pmid: 17003678].
329 Razzi S, et al. Use of a progestogen only preparation containing desogestrel in the treatment of recurrent pelvic pain after conservative surgery for endometriosis. Eur J Obstet Gynecol Reprod Biol. 2007;135(2):188-90. X-3. [pmid: 16963174].
330 Behera M, et al. Laparoscopic findings, histopathologic evaluation, and clinical outcomes in women with chronic pelvic pain after hysterectomy and bilateral salpingo-oophorectomy. J Minim Invasive Gynecol. 2006;13(5):431-5. X-3. [pmid: 16962527].
331 Anderson RU, et al. Sexual dysfunction in men with chronic prostatitis/chronic pelvic pain syndrome: improvement after trigger point release and paradoxical relaxation training. J Urol. 2006;176(4 Pt 1):1534-8. discussion 1538-9. X-2, X-3, X-4. [pmid: 16952676].
332 Haugstad GK, et al. Reliability and validity of a standardized Mensendieck physiotherapy test (SMT). Physiother Theory Pract. 2006;22(4):189-205. X-3, X-4. [pmid: 16920678].
333 Budia A, et al. Value of semen culture in the diagnosis of chronic bacterial prostatitis: a simplified method. Scand J Urol Nephrol. 2006;40(4):326-31. X-2, X-3, X-4. [pmid: 16916775].
334 Penna G, et al. Seminal plasma cytokines and chemokines in prostate inflammation: interleukin 8 as a predictive biomarker in chronic prostatitis/chronic pelvic pain syndrome and benign prostatic hyperplasia. Eur Urol. 2007;51(2):524-33. discussion 533. X-2, X-3, X-4. [pmid: 16905241].
335 Sorensen LP, et al. Chiropractic patients in Denmark 2002: an expanded description and comparison with 1999 survey. J Manipulative Physiol Ther. 2006;29(6):419-24. X-2, X-3, X-4, X-5. [pmid: 16904487].
336 Randolph ME, Reddy DM. Sexual abuse and sexual functioning in a chronic pelvic pain sample. J Child Sex Abus. 2006;15(3):61-78. X-3, X-4. [pmid: 16893819].
337 Starkman JS, et al. Voiding dysfunction following removal of eroded synthetic mid urethral slings. J Urol. 2006;176(3):1040-4. X-3. [pmid: 16890687].
338 Perry CP, Echeverri JD. Hernias as a cause of chronic pelvic pain in women. JSLS. 2006;10(2):212-5. X-2, X-3, X-4. [pmid: 16882422].
339 Chen CH, et al. The self-care strategies of girls with primary dysmenorrhea: a focus group study in Taiwan. Health Care Women Int. 2006;27(5):418-27. X-2, X-3, X-4. [pmid: 16877292].
340 Drozgyik I, Vizer M, Szabo I. Significance of laparoscopy in the management of chronic pelvic pain. Eur J Obstet Gynecol Reprod Biol. 2007;133(2):223-6. X-2, X-3, X-4, X-5. [pmid: 16854515].
341 Blana A, et al. Morbidity associated with repeated transrectal high-intensity focused ultrasound treatment of localized prostate cancer. World J Urol. 2006;24(5):585-90. X-2, X-3, X-4. [pmid: 16850340].
342 Arisan ED, et al. Manganese superoxide dismutase polymorphism in chronic pelvic pain syndrome patients. Prostate Cancer Prostatic Dis. 2006;9(4):426-31. X-2, X-3, X-4. [pmid: 16847469].
343 Swanton A, Iyer L, Reginald PW. Diagnosis, treatment and follow up of women undergoing conscious pain mapping for chronic pelvic pain: a prospective cohort study. BJOG. 2006;113(7):792-6. X-3. [pmid: 16827762].
344 Randolph ME, Reddy DM. Sexual functioning in women with chronic pelvic pain: the impact of depression, support, and abuse. J Sex Res. 2006;43(1):38-45. X-2, X-3, X-4, X-5. [pmid: 16817066].
345 Guney M, Oral B, Mungan T. Efficacy of intrauterine lidocaine for removal of a “lost” intrauterine device: a randomized, controlled trial. Obstet Gynecol. 2006;108(1):119-23. X-2, X-3, X-4, X-5. [pmid: 16816065].
346 Clemens JQ, et al. Prevalence of prostatitis-like symptoms in a managed care population. J Urol. 2006;176(2):593-6. discussion 596. X-2, X-3, X-4. [pmid: 16813895].
347 Smith KJ, Ness RB, Roberts MS. Hospitalization for pelvic inflammatory disease: a cost-effectiveness analysis. Sex Transm Dis. 2007;34(2):108-12. X-2, X-3, X-4. [pmid: 16794559].
348 Vercellini P, et al. Reproductive performance, pain recurrence and disease relapse after conservative surgical treatment for endometriosis: the predictive value of the current classification system. Hum Reprod. 2006;21(10):2679-85. X-2, X-3. [pmid: 16790608].
349 Parker JD, et al. Persistence of dysmenorrhea and nonmenstrual pain after optimal endometriosis surgery may indicate adenomyosis. Fertil Steril. 2006;86(3):711-5. X-2, X-3, X-4. [pmid: 16782099].
350 Leserman J, et al. Identification of diagnostic subtypes of chronic pelvic pain and how subtypes differ in health status and trauma history. Am J Obstet Gynecol. 2006;195(2):554-60. discussion 560-1. X-3, X-4, X-5. [pmid: 16769027].
351 Nickel JC, et al. How does the pre-massage and post-massage 2-glass test compare to the Meares-Stamey 4-glass test in men with chronic prostatitis/chronic pelvic pain syndrome?. J Urol. 2006;176(1):119-24. X-2, X-3, X-4. [pmid: 16753385].
352 Dellabella M, Milanese G, Muzzonigro G. Correlation between ultrasound alterations of the preprostatic sphincter and symptoms in patients with chronic prostatitis-chronic pelvic pain syndrome. J Urol. 2006;176(1):112-8. X-2, X-3, X-4. [pmid: 16753384].
353 Morabito F, et al. Multicenter study on the use of gemcitabine to prevent recurrence of multiple-recurring superficial bladder tumors following intravesical antiblastic agents and/or BCG: evaluation of tolerance. Arch Ital Urol Androl. 2006;78(1):1-4. X-2, X-3, X-4, X-5. [pmid: 16752879].
354 Cox L, et al. Chronic pelvic pain and quality of life after laparoscopy. Eur J Obstet Gynecol Reprod Biol. 2007;132(2):214-9. X-3, X-4, X-5. [pmid: 16730874].
355 Bedaiwy MA, Casper RF. Treatment with leuprolide acetate and hormonal add-back for up to 10 years in stage IV endometriosis patients with chronic pelvic pain. Fertil Steril. 2006;86(1):220-2. X-3. [pmid: 16716325].
356 Chang Y, et al. A modified method of laparoscopic presacral neurectomy for the treatment of midline dysmenorrhea. J Minim Invasive Gynecol. 2006;13(3):211-5. X-2, X-3, X-4. [pmid: 16698527].
357 Abu-Rafea B, et al. Effect of body habitus and parity on insufflated CO2 volume at various intraabdominal pressures during laparoscopic access in women. J Minim Invasive Gynecol. 2006;13(3):205-10. X-3, X-4, X-5. [pmid: 16698526].
358 Nascu PC, et al. Histopathologic findings on uterosacral ligaments in women with chronic pelvic pain and visually normal pelvis at laparoscopy. J Minim Invasive Gynecol. 2006;13(3):201-4. X-3. [pmid: 16698525].
359 Bojahr B, et al. Perioperative complication rate in 1706 patients after a standardized laparoscopic supracervical hysterectomy technique. J Minim Invasive Gynecol. 2006;13(3):183-9. X-2, X-3, X-4. [pmid: 16698522].
360 Turini D, et al. Heat/burning sensation induced by topical application of capsaicin on perineal cutaneous area: new approach in diagnosis and treatment of chronic prostatitis/chronic pelvic pain syndrome?. Urology. 2006;67(5):910-3. X-2, X-3, X-4, X-5. [pmid: 16698350].
361 Allais G, et al. Efficacy and tolerability of almotriptan versus zolmitriptan for the acute treatment of menstrual migraine. Neurol Sci. Suppl 2. 2006;27:S193-7. X-2, X-3, X-4. [pmid: 16688629].
362 Nickel JC, et al. The beneficial effect of alfuzosin 10 mg once daily in ‘real-life’ practice on lower urinary tract symptoms (LUTS), quality of life and sexual dysfunction in men with LUTS and painful ejaculation. BJU Int. 2006;97(6):1242-6. X-2, X-3, X-4. [pmid: 16686719].
363 Paick JS, Lee SC, Ku JH. More effects of extracorporeal magnetic innervation and terazosin therapy than terazosin therapy alone for non-inflammatory chronic pelvic pain syndrome: a pilot study. Prostate Cancer Prostatic Dis. 2006;9(3):261-5. X-2, X-3, X-4. [pmid: 16683008].
364 Mogren IM. Does caesarean section negatively influence the post-partum prognosis of low back pain and pelvic pain during pregnancy?. Eur Spine J. 2007;16(1):115-21. X-2, X-3, X-4. [pmid: 16676151].
365 Korrovits P, et al. The Estonian version of the National Institutes of Health chronic prostatitis symptom index. Andrologia. 2006;38(3):106-9. X-2, X-3, X-4. [pmid: 16669920].
366 Haugstad GK, et al. Mensendieck somatocognitive therapy as treatment approach to chronic pelvic pain: results of a randomized controlled intervention study. Am J Obstet Gynecol. 2006;194(5):1303-10. X-3. [pmid: 16647914].
367 Khadra A, et al. Interleukin-8 levels in seminal plasma in chronic prostatitis/chronic pelvic pain syndrome and nonspecific urethritis. BJU Int. 2006;97(5):1043-6. X-2, X-3, X-4. [pmid: 16643489].
368 Johnson KM, et al. Frequency of mastalgia among women veterans. Association with psychiatric conditions and unexplained pain syndromes. J Gen Intern Med. Suppl 3. 2006;21:S70-5. X-2, X-3, X-4, X-5. [pmid: 16637950].
369 Hosseini A, Herulf M, Ehren I. Measurement of nitric oxide may differentiate between inflammatory and non-inflammatory prostatitis. Scand J Urol Nephrol. 2006;40(2):125-30. X-2, X-3, X-4. [pmid: 16608810].
370 Wu EQ, et al. A retrospective claims database analysis to assess patterns of interstitial cystitis diagnosis. Curr Med Res Opin. 2006;22(3):495-500. X-2, X-3, X-4, X-5. [pmid: 16574033].
371 Hughes L. Physical and psychological variables that influence pain in patients with fibromyalgia. Orthop Nurs. 2006;25(2):112-9. quiz 120-1. X-2, X-3, X-4, X-5. [pmid: 16572028].
372 Milingos S, et al. Laparoscopic evaluation of infertile patients with chronic pelvic pain. Reprod Biomed Online. 2006;12(3):347-53. X-2, X-3, X-4. [pmid: 16569325].
373 Ateya A, et al. Evaluation of prostatic massage in treatment of chronic prostatitis. Urology. 2006;67(4):674-8. X-2, X-3, X-4. [pmid: 16566972].
374 Milingos S, et al. Endometriosis in patients with chronic pelvic pain: is staging predictive of the efficacy of laparoscopic surgery in pain relief?. Gynecol Obstet Invest. 2006;62(1):48-54. X-2, X-3. [pmid: 16543749].
375 Gultasli NZ, et al. The relation between pelvic varicose veins, chronic pelvic pain and lower extremity venous insufficiency in women. Diagn Interv Radiol. 2006;12(1):34-8. X-3, X-4, X-5. [pmid: 16538582].
376 van Balken MR, Vergunst H, Bemelmans BL. Sexual functioning in patients with lower urinary tract dysfunction improves after percutaneous tibial nerve stimulation. Int J Impot Res. 2006;18(5):470-5. discussion 476. X-3. [pmid: 16528293].
377 Lorencatto C, et al. Depression in women with endometriosis with and without chronic pelvic pain. Acta Obstet Gynecol Scand. 2006;85(1):88-92. X-2, X-3. [pmid: 16521687].
378 Kim HS, et al. Embolotherapy for pelvic congestion syndrome: long-term results. J Vasc Interv Radiol. 2006;17(2 Pt 1):289-97. X-3. [pmid: 16517774].
379 Angioni S, et al. Laparoscopic excision of posterior vaginal fornix in the treatment of patients with deep endometriosis without rectum involvement: surgical treatment and long-term follow-up. Hum Reprod. 2006;21(6):1629-34. X-3. [pmid: 16495305].
380 Fauconnier A, et al. Mobile uterine retroversion is associated with dyspareunia and dysmenorrhea in an unselected population of women. Eur J Obstet Gynecol Reprod Biol. 2006;127(2):252-6. X-2, X-3, X-4, X-5. [pmid: 16494992].
381 Price J, et al. Attitudes of women with chronic pelvic pain to the gynaecological consultation: a qualitative study. BJOG. 2006;113(4):446-52. X-3, X-4. [pmid: 16489938].
382 Okaro E, et al. The use of ultrasound-based ‘soft markers’ for the prediction of pelvic pathology in women with chronic pelvic pain--can we reduce the need for laparoscopy?. BJOG. 2006;113(3):251-6. X-3, X-4, X-5. [pmid: 16487194].
383 Bachmann GA, et al. Chronic vulvar and other gynecologic pain: prevalence and characteristics in a self-reported survey. J Reprod Med. 2006;51(1):3-9. X-2, X-3, X-4. [pmid: 16482769].
384 Clemens JQ, et al. Predictors of symptom severity in patients with chronic prostatitis and interstitial cystitis. J Urol. 2006;175(3 Pt 1):963-6. discussion 967. X-2, X-3, X-4. [pmid: 16469592].
385 Propert KJ, et al. Responsiveness of the National Institutes of Health Chronic Prostatitis Symptom Index (NIH-CPSI). Qual Life Res. 2006;15(2):299-305. X-2, X-3, X-4. [pmid: 16468084].
386 Cheah PY, et al. Reliability and validity of the National Institutes of Health Chronic Prostatitis Symptom Index in a Malaysian population. World J Urol. 2006;24(1):79-87. X-2, X-3, X-4. [pmid: 16465553].
387 Beste TM, Daucher JA, Holbert D. Humidified compared with dry, heated carbon dioxide at laparoscopy to reduce pain. Obstet Gynecol. 2006;107(2 Pt 1):263-8. X-2, X-3, X-4, X-5. [pmid: 16449110].
388 Wu EQ, et al. Interstitial Cystitis: Cost, treatment and co-morbidities in an employed population. Pharmacoeconomics. 2006;24(1):55-65. X-2, X-3, X-4. [pmid: 16445303].
389 Chen WM, et al. Combination regimen in the treatment of chronic prostatitis. Arch Androl. 2006;52(2):117-21. X-2, X-3, X-4. [pmid: 16443588].
390 Nadler RB, et al. Prostate-specific antigen test in diagnostic evaluation of chronic prostatitis/chronic pelvic pain syndrome. Urology. 2006;67(2):337-42. X-2, X-3, X-4. [pmid: 16442595].
391 Stones RW, Lawrence WT, Selfe SA. Lasting impressions: influence of the initial hospital consultation for chronic pelvic pain on dimensions of patient satisfaction at follow-up. J Psychosom Res. 2006;60(2):163-7. X-2, X-3, X-4, X-5. [pmid: 16439269].
392 Lee CB, et al. Preliminary experience with a terpene mixture versus ibuprofen for treatment of category III chronic prostatitis/chronic pelvic pain syndrome. World J Urol. 2006;24(1):55-60. X-2, X-3, X-4. [pmid: 16418872].
393 Valentini V, et al. Preoperative hyperfractionated chemoradiation for locally recurrent rectal cancer in patients previously irradiated to the pelvis: A multicentric phase II study. Int J Radiat Oncol Biol Phys. 2006;64(4):1129-39. X-2, X-3, X-4. [pmid: 16414206].
394 Elist J. Effects of pollen extract preparation Prostat/Poltit on lower urinary tract symptoms in patients with chronic nonbacterial prostatitis/chronic pelvic pain syndrome: a randomized, double-blind, placebo-controlled study. Urology. 2006;67(1):60-3. X-2, X-3, X-4. [pmid: 16413333].
395 Propert KJ, et al. A prospective study of symptoms and quality of life in men with chronic prostatitis/chronic pelvic pain syndrome: the National Institutes of Health Chronic Prostatitis Cohort study. J Urol. 2006;175(2):619-23. discussion 623. X-2, X-3, X-4. [pmid: 16407009].
396 Crade M, Pham V. Ultrasound examination of the sigmoid colon: possible new diagnostic tool for irritable bowel syndrome. Ultrasound Obstet Gynecol. 2006;27(2):206-9. X-2, X-3, X-4, X-5. [pmid: 16404710].
397 Mogren IM. BMI, pain and hyper-mobility are determinants of long-term outcome for women with low back pain and pelvic pain during pregnancy. Eur Spine J. 2006;15(7):1093-102. X-2, X-3, X-4. [pmid: 16404613].
398 Henkel R, et al. Chronic pelvic pain syndrome/chronic prostatitis affect the acrosome reaction in human spermatozoa. World J Urol. 2006;24(1):39-44. X-2, X-3, X-4. [pmid: 16404593].
399 Paulson JD, Delgado M. Chronic pelvic pain: the occurrence of interstitial cystitis in a gynecological population. JSLS. 2005;9(4):426-30. X-3. [pmid: 16381360].
400 Thomas E, Moss-Morris R, Faquhar C. Coping with emotions and abuse history in women with chronic pelvic pain. J Psychosom Res. 2006;60(1):109-12. X-3, X-4, X-5. [pmid: 16380318].
401 van Balken MR, Vergunst H, Bemelmans BL. Prognostic factors for successful percutaneous tibial nerve stimulation. Eur Urol. 2006;49(2):360-5. X-3. [pmid: 16359781].
402 Vignali M, et al. Surgical treatment of deep endometriosis and risk of recurrence. J Minim Invasive Gynecol. 2005;12(6):508-13. X-3, X-4, X-5. [pmid: 16337578].
403 Abu-Rafea B, et al. High-pressure laparoscopic entry does not adversely affect cardiopulmonary function in healthy women. J Minim Invasive Gynecol. 2005;12(6):475-9. X-3, X-4, X-5. [pmid: 16337573].
404 Gehrich AP, et al. Chronic urinary retention and pelvic floor hypertonicity after surgery for endometriosis: a case series. Am J Obstet Gynecol. 2005;193(6):2133-7. X-3. [pmid: 16325629].
405 Magtibay PM, et al. Ovarian remnant syndrome. Am J Obstet Gynecol. 2005;193(6):2062-6. X-2, X-3, X-4. [pmid: 16325616].
406 Seng JS, et al. Posttraumatic stress disorder and physical comorbidity among female children and adolescents: results from service-use data. Pediatrics. 2005;116(6):e767-76. X-2, X-3, X-4. [pmid: 16322133].
407 Thomson JC, Redwine DB. Chronic pelvic pain associated with autoimmunity and systemic and peritoneal inflammation and treatment with immune modification. J Reprod Med. 2005;50(10):745-58. X-2, X-3, X-4, X-5. [pmid: 16320555].
408 Buchweitz O, et al. COX-2 overexpression in peritoneal lesions is correlated with nonmenstrual chronic pelvic pain. Eur J Obstet Gynecol Reprod Biol. 2006;124(2):216-21. X-3, X-4, X-5. [pmid: 16309818].
409 Silva EG, et al. Association of low-grade endometrioid carcinoma of the uterus and ovary with undifferentiated carcinoma: a new type of dedifferentiated carcinoma?. Int J Gynecol Pathol. 2006;25(1):52-8. X-2, X-3, X-4. [pmid: 16306785].
410 Parker JD, et al. Adhesion formation after laparoscopic excision of endometriosis and lysis of adhesions. Fertil Steril. 2005;84(5):1457-61. X-3, X-4, X-5. [pmid: 16275244].
411 Vercellini P, et al. Treatment of symptomatic rectovaginal endometriosis with an estrogen-progestogen combination versus low-dose norethindrone acetate. Fertil Steril. 2005;84(5):1375-87. X-3. [pmid: 16275232].
412 Karakiewicz PI, et al. French-Canadian linguistic validation of the NIH Chronic Prostatitis Symptom Index. Can J Urol. 2005;12(5):2816-23. X-2, X-3, X-4. [pmid: 16274517].
413 Bedaiwy MA, et al. Peritoneal fluid leptin is associated with chronic pelvic pain but not infertility in endometriosis patients. Hum Reprod. 2006;21(3):788-91. X-3, X-4, X-5. [pmid: 16269446].
414 Wallis L. When rites are wrong. Nurs Stand. 2005;20(4):24-6. X-1, X-2, X-3, X-4.
415 Atwal G, et al. Uterine innervation after hysterectomy for chronic pelvic pain with, and without, endometriosis. Am J Obstet Gynecol. 2005;193(5):1650-5. X-3, X-4. [pmid: 16260205].
416 Tokushige N, et al. High density of small nerve fibres in the functional layer of the endometrium in women with endometriosis. Hum Reprod. 2006;21(3):782-7. X-3, X-4. [pmid: 16253968].
417 Perry CP, Presthus J, Nieves A. Laparoscopic uterine suspension for pain relief: a multicenter study. J Reprod Med. 2005;50(8):567-70. X-3. [pmid: 16220760].
418 Berger RE. Predictors of quality of life and pain in chronic prostatitis/chronic pelvic pain syndrome: findings from the National Institutes of Health Chronic Prostatitis Cohort Study. J Urol. 2005;174(5):1842-3. X-2, X-3, X-4.
419 Hefler LA, et al. Role of the vaginally administered aromatase inhibitor anastrozole in women with rectovaginal endometriosis: a pilot study. Fertil Steril. 2005;84(4):1033-6. X-3. [pmid: 16213868].
420 Klemm P, et al. Laparoscopic and vaginal repair of uterine scar dehiscence following cesarean section as detected by ultrasound. J Perinat Med. 2005;33(4):324-31. X-3. [pmid: 16207118].
421 Candiani M. Current guidelines for treatment of endometriosis without laparoscopy. Drugs Today (Barc). Suppl A. 2005;41:11-5. X-1, X-2, X-3. [pmid: 16200220].
422 Olive DL. Empirical therapy with leuprorelin acetate for endometriosis in the United States. Drugs Today (Barc). Suppl A. 2005;41:5-10. X-1, X-2, X-3. [pmid: 16200219].
423 Stavroulis AI, et al. Laparoscopic treatment of endometriosis in teenagers. Eur J Obstet Gynecol Reprod Biol. 2006;125(2):248-50. X-2, X-3. [pmid: 16188371].
424 Ullrich PM, et al. Stress is associated with subsequent pain and disability among men with nonbacterial prostatitis/pelvic pain. Ann Behav Med. 2005;30(2):112-8. X-2, X-3, X-4. [pmid: 16173907].
425 Wykes CB, et al. Efficacy of laparoscopic excision of visually diagnosed peritoneal endometriosis in the treatment of chronic pelvic pain. Eur J Obstet Gynecol Reprod Biol. 2006;125(1):129-33. X-2, X-3, X-4, X-5. [pmid: 16169150].
426 Hetrick DC, et al. Pelvic floor electromyography in men with chronic pelvic pain syndrome: a case-control study. Neurourol Urodyn. 2006;25(1):46-9. X-2, X-3, X-4. [pmid: 16167354].
427 Yasmin H, Bombieri L, Hollingworth J. What happens to women with chronic pelvic pain after a negative [normal] laparoscopy?. J Obstet Gynaecol. 2005;25(3):283-5. X-3. [pmid: 16147737].
428 Hill NC, et al. Safety of the Helica Thermal Coagulator in treatment of early stage endometriosis. J Obstet Gynaecol. 2005;25(1):52-4. X-3. [pmid: 16147696].
429 Ness RB, et al. Effectiveness of treatment strategies of some women with pelvic inflammatory disease: a randomized trial. Obstet Gynecol. 2005;106(3):573-80. X-2, X-3, X-4, X-5. [pmid: 16135590].
430 de Sa Rosa e de Silva AC, et al. Routine office hysteroscopy in the investigation of infertile couples before assisted reproduction. J Reprod Med. 2005;50(7):501-6. X-4. [pmid: 16130847].
431 Szendei G, et al. Is there any correlation between stages of endometriosis and severity of chronic pelvic pain? Possibilities of treatment. Gynecol Endocrinol. 2005;21(2):93-100. X-3, X-4. [pmid: 16109595].
432 Pontari MA, et al. A case-control study of risk factors in men with chronic pelvic pain syndrome. BJU Int. 2005;96(4):559-65. X-2, X-3, X-4. [pmid: 16104910].
433 Fleisch MC, et al. Radical resection of invasive endometriosis with bowel or bladder involvement--long-term results. Eur J Obstet Gynecol Reprod Biol. 2005;123(2):224-9. X-3. [pmid: 16102887].
434 Hartung O, et al. Endovascular stenting in the treatment of pelvic vein congestion caused by nutcracker syndrome: lessons learned from the first five cases. J Vasc Surg. 2005;42(2):275-80. X-3. [pmid: 16102626].
435 Berger RE. Urologic myofascial pain syndromes. J Urol. 2005;174(3):942. X-1, X-2, X-3, X-4, X-5.
436 Gonen M, et al. Prevalence of premature ejaculation in Turkish men with chronic pelvic pain syndrome. J Androl. 2005;26(5):601-3. X-2, X-3, X-4. [pmid: 16088036].
437 Amsterdam LL, et al. Anastrazole and oral contraceptives: a novel treatment for endometriosis. Fertil Steril. 2005;84(2):300-4. X-3. [pmid: 16084868].
438 Marchino GL, et al. Diagnosis of pelvic endometriosis with use of macroscopic versus histologic findings. Fertil Steril. 2005;84(1):12-5. X-3, X-4, X-5. [pmid: 16009147].
439 FitzGerald MP, et al. What is the pain of interstitial cystitis like?. Int Urogynecol J Pelvic Floor Dysfunct. 2006;17(1):69-72. X-2, X-3, X-4, X-5. [pmid: 15995791].
440 Einarsson JI, Henao G, Young AE. Topical analgesia for endometrial biopsy: a randomized controlled trial. Obstet Gynecol. 2005;106(1):128-30. X-2, X-3, X-4, X-5. [pmid: 15994627].
441 Perry CP, Hantes JM. Diagnosis and laparoscopic repair of type I obturator hernia in women with chronic neuralgic pain. JSLS. 2005;9(2):138-41. X-2, X-3, X-4. [pmid: 15984699].
442 Dinis P, et al. The distribution of sensory fibers immunoreactive for the TRPV1 (capsaicin) receptor in the human prostate. Eur Urol. 2005;48(1):162-7. X-2, X-3, X-4. [pmid: 15967267].
443 Wright J, et al. A randomized trial of excision versus ablation for mild endometriosis. Fertil Steril. 2005;83(6):1830-6. X-3. [pmid: 15950657].
444 Yilmaz U, et al. Toe spreading ability in men with chronic pelvic pain syndrome. BMC Urol. 2005;5:11. X-2, X-3, X-4. [pmid: 15949041].
445 Anderson RU, et al. Integration of myofascial trigger point release and paradoxical relaxation training treatment of chronic pelvic pain in men. J Urol. 2005;174(1):155-60. X-2, X-3, X-4. [pmid: 15947608].
446 Al-Hadithi HN, et al. Absence of bacterial and viral DNA in bladder biopsies from patients with interstitial cystitis/chronic pelvic pain syndrome. J Urol. 2005;174(1):151-4. X-2, X-3, X-4, X-5. [pmid: 15947607].
447 Reporting of chlamydial infection--Massachusetts, January-June 2003. MMWR Morb Mortal Wkly Rep. 2005;54(22):558-60. X-2, X-3, X-4, X-5. [pmid: 15944526].
448 Laslett M, et al. Agreement between diagnoses reached by clinical examination and available reference standards: a prospective study of 216 patients with lumbopelvic pain. BMC Musculoskelet Disord. 2005;6:28. X-2, X-3, X-4, X-5. [pmid: 15943873].
449 Pezzone MA, Liang R, Fraser MO. A model of neural cross-talk and irritation in the pelvis: implications for the overlap of chronic pelvic pain disorders. Gastroenterology. 2005;128(7):1953-64. X-2, X-3, X-4. [pmid: 15940629].
450 Strebel RT, et al. Chronic scrotal pain syndrome: management among urologists in Switzerland. Eur Urol. 2005;47(6):812-6. X-2, X-3, X-4. [pmid: 15925078].
451 Giubilei G, et al. The Italian version of the National Institutes of Health Chronic Prostatitis Symptom Index. Eur Urol. 2005;47(6):805-11. X-2, X-3, X-4. [pmid: 15925077].
452 Champion JD, et al. Relationship of abuse and pelvic inflammatory disease risk behavior in minority adolescents. J Am Acad Nurse Pract. 2005;17(6):234-41. X-4. [pmid: 15924566].
453 Berker B, et al. Laparoscopic appendectomy in patients with endometriosis. J Minim Invasive Gynecol. 2005;12(3):206-9. X-2, X-3, X-4, X-5. [pmid: 15922976].
454 Ghomi A, Hantes J, Lotze EC. Incidence of cyclical bleeding after laparoscopic supracervical hysterectomy. J Minim Invasive Gynecol. 2005;12(3):201-5. X-3, X-4, X-5. [pmid: 15922975].
455 de Oliveira Bernardes N, Bahamondes L. Intravaginal electrical stimulation for the treatment of chronic pelvic pain. J Reprod Med. 2005;50(4):267-72. X-3. [pmid: 15916211].
456 Elhilali MM, et al. Sacral neuromodulation: long-term experience of one center. Urology. 2005;65(6):1114-7. X-3, X-4. [pmid: 15913732].
457 Chopin N, et al. Operative management of deeply infiltrating endometriosis: results on pelvic pain symptoms according to a surgical classification. J Minim Invasive Gynecol. 2005;12(2):106-12. X-2, X-3, X-4. [pmid: 15904612].
458 Stanford EJ, Koziol J, Feng A. The prevalence of interstitial cystitis, endometriosis, adhesions, and vulvar pain in women with chronic pelvic pain. J Minim Invasive Gynecol. 2005;12(1):43-9. X-3. [pmid: 15904598].
459 Harel Z, et al. Adolescents' experience with the combined estrogen and progestin transdermal contraceptive method Ortho Evra. J Pediatr Adolesc Gynecol. 2005;18(2):85-90. X-2, X-3, X-4. [pmid: 15897103].
460 Turner JA, et al. Health concerns of patients with nonbacterial prostatitis/pelvic pain. Arch Intern Med. 2005;165(9):1054-9. X-2, X-3, X-4. [pmid: 15883246].
461 Rowe E, et al. A prospective, randomized, placebo controlled, double-blind study of pelvic electromagnetic therapy for the treatment of chronic pelvic pain syndrome with 1 year of followup. J Urol. 2005;173(6):2044-7. X-2, X-3, X-4. [pmid: 15879822].
462 Haggerty CL, et al. Predictors of chronic pelvic pain in an urban population of women with symptoms and signs of pelvic inflammatory disease. Sex Transm Dis. 2005;32(5):293-9. X-2, X-3, X-4, X-5. [pmid: 15849530].
463 Ventolini G, Horowitz GM, Long R. Endometriosis in adolescence: a long-term follow-up fecundability assessment. Reprod Biol Endocrinol. 2005;3:14. X-2, X-3, X-4. [pmid: 15845149].
464 Gardella C, et al. Prevalence of hysterectomy and associated factors in women Veterans Affairs patients. J Reprod Med. 2005;50(3):166-72. X-2, X-3, X-4, X-5. [pmid: 15841928].
465 Goldmeier D, et al. Treatment of category III A prostatitis with zafirlukast: a randomized controlled feasibility study. Int J STD AIDS. 2005;16(3):196-200. X-2, X-3, X-4. [pmid: 15829018].
466 Cornel EB, et al. The effect of biofeedback physical therapy in men with Chronic Pelvic Pain Syndrome Type III. Eur Urol. 2005;47(5):607-11. X-2, X-3, X-4. [pmid: 15826751].
467 Spinhoven P, et al. Trauma and dissociation in conversion disorder and chronic pelvic pain. Int J Psychiatry Med. 2004;34(4):305-18. X-2, X-3, X-4, X-5. [pmid: 15825581].
468 Leibovici D, et al. Symptomatic local recurrence of prostate carcinoma after radiation therapy. Cancer. 2005;103(10):2060-6. X-2, X-3, X-4. [pmid: 15822114].
469 Nezhat C, et al. Laparoscopic management of ovarian remnant. Fertil Steril. 2005;83(4):973-8. X-2, X-3, X-4, X-5. [pmid: 15820809].
470 Lee RA, West RM, Wilson JD. The response to sertraline in men with chronic pelvic pain syndrome. Sex Transm Infect. 2005;81(2):147-9. X-2, X-3, X-4. [pmid: 15800093].
471 Leippold T, et al. Sacral magnetic stimulation in non-inflammatory chronic pelvic pain syndrome. BJU Int. 2005;95(6):838-41. X-2, X-3, X-4. [pmid: 15794794].
472 Bradshaw HD, et al. Towards a better understanding of involuntary detrusor activity. BJU Int. 2005;95(6):799-803. X-2, X-3, X-4, X-5. [pmid: 15794786].
473 Chung MK, Chung RP, Gordon D. Interstitial cystitis and endometriosis in patients with chronic pelvic pain: The “Evil Twins” syndrome. JSLS. 2005;9(1):25-9. X-2, X-3. [pmid: 15791965].
474 Petta CA, et al. Randomized clinical trial of a levonorgestrel-releasing intrauterine system and a depot GnRH analogue for the treatment of chronic pelvic pain in women with endometriosis. Hum Reprod. 2005;20(7):1993-8. X-2. [pmid: 15790607].
475 Chao YM, et al. Appropriateness of hysterectomy in Taiwan. J Formos Med Assoc. 2005;104(2):107-12. X-2, X-3, X-4, X-5. [pmid: 15765165].
476 Andersen B, et al. Opportunistic screening of young men for urogenital Chlamydia trachomatis infection in general practice. Scand J Infect Dis. 2005;37(1):35-9. X-2, X-3, X-4. [pmid: 15764188].
477 Heatley MK. The association between clinical and pathological features in histologically identified chronic endometritis. J Obstet Gynaecol. 2004;24(7):801-3. X-2, X-3, X-4, X-5. [pmid: 15763793].
478 Campagnacci R, et al. Laparoscopic colorectal resection for endometriosis. Surg Endosc. 2005;19(5):662-4. X-3. [pmid: 15759190].
479 Nickel JC, et al. Pentosan polysulfate sodium therapy for men with chronic pelvic pain syndrome: a multicenter, randomized, placebo controlled study. J Urol. 2005;173(4):1252-5. X-2, X-3, X-4. [pmid: 15758763].
480 Poleshuck EL, et al. Contributions of physical and sexual abuse to women's experiences with chronic pelvic pain. J Reprod Med. 2005;50(2):91-100. X-3. [pmid: 15755045].
481 Hassa H, Tanir HM, Uray M. Symptom distribution among infertile and fertile endometriosis cases with different stages and localisations. Eur J Obstet Gynecol Reprod Biol. 2005;119(1):82-6. X-3, X-4, X-5. [pmid: 15734090].
482 Leibovici D, et al. Salvage surgery for bulky local recurrence of prostate cancer following radical prostatectomy. J Urol. 2005;173(3):781-3. X-2, X-3, X-4. [pmid: 15711269].
483 Huber AV, et al. Systemic HCG treatment in patients with endometriosis: a new perspective for a painful disease. Wien Klin Wochenschr. 2004;116(24):839-43. X-3. [pmid: 15690968].
484 Zondervan KT, et al. Multivariate genetic analysis of chronic pelvic pain and associated phenotypes. Behav Genet. 2005;35(2):177-88. X-4. [pmid: 15685430].
485 Shoskes DA, Thomas KD, Gomez E. Anti-nanobacterial therapy for men with chronic prostatitis/chronic pelvic pain syndrome and prostatic stones: preliminary experience. J Urol. 2005;173(2):474-7. X-2, X-3, X-4. [pmid: 15643213].
486 Kanberoglu K, et al. Magnetic resonance imaging in osteomalacic insufficiency fractures of the pelvis. Clin Radiol. 2005;60(1):105-11. X-3. [pmid: 15642300].
487 Parsons CL, et al. Quantifying symptoms in men with interstitial cystitis/prostatitis, and its correlation with potassium-sensitivity testing. BJU Int. 2005;95(1):86-90. X-2, X-3, X-4. [pmid: 15638901].
488 Liu FS, et al. Management of pelvic lymphocysts by ultrasound-guided aspiration and minocycline sclerotherapy. Gynecol Obstet Invest. 2005;59(3):130-3. X-3. [pmid: 15627779].
489 Harris HA, et al. A selective estrogen receptor-beta agonist causes lesion regression in an experimentally induced model of endometriosis. Hum Reprod. 2005;20(4):936-41. X-2, X-3, X-4. [pmid: 15618247].
490 Tripp DA, et al. Predictors of quality of life and pain in chronic prostatitis/chronic pelvic pain syndrome: findings from the National Institutes of Health Chronic Prostatitis Cohort Study. BJU Int. 2004;94(9):1279-82. X-2, X-3, X-4. [pmid: 15610105].
491 Atmaca R, et al. Changes in serum CA-125 levels after laparotomy?. Eur J Gynaecol Oncol. 2004;25(6):733-4. X-2, X-3, X-4, X-5. [pmid: 15597853].
492 Kastner C, et al. Cooled transurethral microwave thermotherapy for intractable chronic prostatitis--results of a pilot study after 1 year. Urology. 2004;64(6):1149-54. X-2, X-3, X-4. [pmid: 15596188].
493 Alborzi S, et al. A prospective, randomized study comparing laparoscopic ovarian cystectomy versus fenestration and coagulation in patients with endometriomas. Fertil Steril. 2004;82(6):1633-7. X-2, X-3. [pmid: 15589870].
494 Squifflet J, Donnez J. Endometriosis is not only a gynecologic disease. Acta Gastroenterol Belg. 2004;67(3):272-7. X-1, X-2, X-3, X-4. [pmid: 15587334].
495 Lamvu G, et al. Vaginal apex resection: a treatment option for vaginal apex pain. Obstet Gynecol. 2004;104(6):1340-6. X-3. [pmid: 15572500].
496 Chapron C, et al. Presurgical diagnosis of posterior deep infiltrating endometriosis based on a standardized questionnaire. Hum Reprod. 2005;20(2):507-13. X-3, X-4, X-5. [pmid: 15567874].
497 Chung MK. Interstitial cystitis in persistent posthysterectomy chronic pelvic pain. JSLS. 2004;8(4):329-33. X-3. [pmid: 15554275].
498 Kacmar JE, Weitzen S. Identification of educational objectives for obstetrics and gynecology residents in the ambulatory setting. Am J Obstet Gynecol. 2004;191(5):1757-61. X-2, X-3, X-4, X-5. [pmid: 15547560].
499 Volkmer BG, et al. Cystectomy and orthotopic ileal neobladder: the impact on female sexuality. J Urol. 2004;172(6 Pt 1):2353-7. X-2, X-3, X-4. [pmid: 15538266].
500 Forrest JB, Schmidt S. Interstitial cystitis, chronic nonbacterial prostatitis and chronic pelvic pain syndrome in men: a common and frequently identical clinical entity. J Urol. 2004;172(6 Pt 2):2561-2. X-2, X-3, X-4. [pmid: 15538208].
501 Krieger JN, Riley DE. Chronic prostatitis: Charlottesville to Seattle. J Urol. 2004;172(6 Pt 2):2557-60. X-2, X-3, X-4. [pmid: 15538207].
502 Cheah PY, et al. Initial, long-term, and durable responses to terazosin, placebo, or other therapies for chronic prostatitis/chronic pelvic pain syndrome. Urology. 2004;64(5):881-6. X-2, X-3, X-4. [pmid: 15533470].
503 Cheewadhanaraks S. Effect of tubal ligation on pelvic endometriosis externa in multiparous women with chronic pelvic pain. J Med Assoc Thai. 2004;87(7):735-9. X-2, X-3, X-4, X-5. [pmid: 15521225].
504 Atmaca R, et al. Is there a change in serum CA-125 levels after laparoscopy?. Eur J Gynaecol Oncol. 2004;25(5):625-7. X-2, X-3, X-4, X-5. [pmid: 15493182].
505 Alexander RB, et al. Ciprofloxacin or tamsulosin in men with chronic prostatitis/chronic pelvic pain syndrome: a randomized, double-blind trial. Ann Intern Med. 2004;141(8):581-9. X-2, X-3, X-4. [pmid: 15492337].
506 Summaries for patients. Treating men with chronic prostatitis/chronic pelvic pain syndrome. Ann Intern Med. 2004;141(8):18. X-1, X-2, X-3, X-4.
507 Hu D, Hook EW 3rd, Goldie SJ. Screening for Chlamydia trachomatis in women 15 to 29 years of age: a cost-effectiveness analysis. Ann Intern Med. 2004;141(7):501-13. X-1, X-2, X-3, X-4, X-5. [pmid: 15466767].
508 Hilden M, et al. A history of sexual abuse and health: a Nordic multicentre study. BJOG. 2004;111(10):1121-7. X-2, X-3, X-4, X-5. [pmid: 15383115].
509 Latthe PM, et al. Variation in practice of laparoscopic uterosacral nerve ablation: a European survey. J Obstet Gynaecol. 2004;24(5):547-51. X-2, X-3, X-4, X-5. [pmid: 15369938].
510 Dunphy EJ, et al. Identification of antigen-specific IgG in sera from patients with chronic prostatitis. J Clin Immunol. 2004;24(5):492-502. X-2, X-3, X-4. [pmid: 15359108].
511 Quinn M. Endometriosis: the consequence of neurological dysfunction?. Med Hypotheses. 2004;63(4):602-8. X-1, X-2, X-3, X-4, X-5. [pmid: 15325003].
512 Chronic pelvic pain increasingly more prevalent. AWHONN Lifelines. 2004;8(3):207-8. X-1, X-2, X-3, X-4, X-5. [pmid: 15305593].
513 Cavallotti D, et al. Early complications of prenatal invasive diagnostics: perspective analysis. Acta Biomed. Suppl 1. 2004;75:23-6. X-2, X-3, X-4, X-5. [pmid: 15301285].
514 Cobellis L, et al. The treatment with a COX-2 specific inhibitor is effective in the management of pain related to endometriosis. Eur J Obstet Gynecol Reprod Biol. 2004;116(1):100-2. X-3. [pmid: 15294376].
515 Quinn M. Obstetric denervation-gynaecological reinnervation: disruption of the inferior hypogastric plexus in childbirth as a source of gynaecological symptoms. Med Hypotheses. 2004;63(3):390-3. X-1, X-2, X-3, X-4, X-5. [pmid: 15288354].
516 Wadhwa L, et al. Severity, affect, family and environment (SAFE) approach to evaluate chronic pelvic pain in adolescent girls. Indian J Med Sci. 2004;58(7):275-82. X-2, X-3, X-4, X-5. [pmid: 15286418].
517 Honjo H, et al. Effects of acupuncture for chronic pelvic pain syndrome with intrapelvic venous congestion: preliminary results. Int J Urol. 2004;11(8):607-12. X-2, X-3, X-4. [pmid: 15285750].
518 Ness RB, et al. Condom use and the risk of recurrent pelvic inflammatory disease, chronic pelvic pain, or infertility following an episode of pelvic inflammatory disease. Am J Public Health. 2004;94(8):1327-9. X-2, X-3, X-4, X-5. [pmid: 15284036].
519 Chen RC, Nickel JC. Acupuncture for chronic prostatitis/chronic pelvic pain syndrome. Curr Urol Rep. 2004;5(4):305-8. X-2, X-3, X-4. [pmid: 15260934].
520 Atkinson MJ, et al. The Self-Perception and Relationships Tool (S-PRT): a novel approach to the measurement of subjective health-related quality of life. Health Qual Life Outcomes. 2004;2:36. X-2, X-3, X-4, X-5. [pmid: 15257754].
521 Nickel JC, et al. Failure of a monotherapy strategy for difficult chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2004;172(2):551-4. X-2, X-3, X-4. [pmid: 15247727].
522 Yilmaz U, et al. Intravesical potassium chloride sensitivity test in men with chronic pelvic pain syndrome. J Urol. 2004;172(2):548-50. X-2, X-3, X-4. [pmid: 15247726].
523 Shoskes DA, et al. Impact of post-ejaculatory pain in men with category III chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2004;172(2):542-7. X-2, X-3, X-4. [pmid: 15247725].
524 Turner JA, et al. Prognosis of patients with new prostatitis/pelvic pain syndrome episodes. J Urol. 2004;172(2):538-41. X-2, X-3, X-4. [pmid: 15247724].
525 Potlog-Nahari C, et al. CD10 immunohistochemical staining enhances the histological detection of endometriosis. Fertil Steril. 2004;82(1):86-92. X-3, X-4. [pmid: 15236994].
526 Calhaz-Jorge C, et al. Clinical predictive factors for endometriosis in a Portuguese infertile population. Hum Reprod. 2004;19(9):2126-31. X-2, X-3, X-4, X-5. [pmid: 15229202].
527 Burkhard FC, et al. Urinary urgency and frequency, and chronic urethral and/or pelvic pain in females. Can doxycycline help?. J Urol. 2004;172(1):232-5. X-2, X-3, X-4, X-5. [pmid: 15201781].
528 Demco L. Laparoscopic spectral analysis of endometriosis. J Am Assoc Gynecol Laparosc. 2004;11(2):219-22. X-3, X-4. [pmid: 15200778].
529 Demco L. Pain mapping of adhesions. J Am Assoc Gynecol Laparosc. 2004;11(2):181-3. X-3, X-4. [pmid: 15200771].
530 Cambron JA, et al. Recruitment and accrual of women in a placebo-controlled clinical pilot study on manual therapy. J Manipulative Physiol Ther. 2004;27(5):299-305. X-3, X-4. [pmid: 15195037].
531 Goff BA, et al. Frequency of symptoms of ovarian cancer in women presenting to primary care clinics. JAMA. 2004;291(22):2705-12. X-2, X-3, X-4, X-5. [pmid: 15187051].
532 Turner JA, et al. Healthcare use and costs of primary and secondary care patients with prostatitis. Urology. 2004;63(6):1031-5. X-2, X-3, X-4. [pmid: 15183941].
533 Schneider H, et al. Two-year experience with the german-translated version of the NIH-CPSI in patients with CP/CPPS. Urology. 2004;63(6):1027-30. X-2, X-3, X-4. [pmid: 15183940].
534 Demco LA, Medina M. Intravesicular pain mapping. Adv Exp Med Biol. 2003;539(Pt B):655-81. X-1, X-2, X-3, X-4, X-5. [pmid: 15176318].
535 Frishman GN, et al. The use of intrauterine lidocaine to minimize pain during hysterosalpingography: a randomized trial. Obstet Gynecol. 2004;103(6):1261-6. X-2, X-3, X-4, X-5. [pmid: 15172862].
536 Porru D, et al. Different clinical presentation of interstitial cystitis syndrome. Int Urogynecol J Pelvic Floor Dysfunct. 2004;15(3):198-202. X-2, X-3, X-4. [pmid: 15168001].
537 Nickel JC, et al. A randomized placebo-controlled multicentre study to evaluate the safety and efficacy of finasteride for male chronic pelvic pain syndrome (category IIIA chronic nonbacterial prostatitis). BJU Int. 2004;93(7):991-5. X-2, X-3, X-4. [pmid: 15142149].
538 Gupta JK, et al. Patient anxiety and experiences associated with an outpatient “one-stop” “see and treat” hysteroscopy clinic. Surg Endosc. 2004;18(7):1099-104. X-2, X-3, X-4, X-5. [pmid: 15136927].
539 Learman LA, et al. Hysterectomy versus expanded medical treatment for abnormal uterine bleeding: clinical outcomes in the medicine or surgery trial. Obstet Gynecol. 2004;103(5 Pt 1):824-33. X-2, X-3, X-4. [pmid: 15121552].
540 Heinberg LJ, et al. Psychological factors in pelvic/urogenital pain: the influence of site of pain versus sex. Pain. 2004;108(1-2):88-94. X-3. [pmid: 15109511].
541 Zullo F, et al. Long-term effectiveness of presacral neurectomy for the treatment of severe dysmenorrhea due to endometriosis. J Am Assoc Gynecol Laparosc. 2004;11(1):23-8. X-2, X-3. [pmid: 15104826].
542 van Zwienen CM, et al. Triple pelvic ring fixation in patients with severe pregnancy-related low back and pelvic pain. Spine (Phila Pa 1976). 2004;29(4):478-84. X-2, X-3, X-4. [pmid: 15094546].
543 Jarvis SK, et al. Pilot study of botulinum toxin type A in the treatment of chronic pelvic pain associated with spasm of the levator ani muscles. Aust N Z J Obstet Gynaecol. 2004;44(1):46-50. X-3. [pmid: 15089868].
544 Peters KM, Konstandt D. Sacral neuromodulation decreases narcotic requirements in refractory interstitial cystitis. BJU Int. 2004;93(6):777-9. X-3. [pmid: 15049989].
545 Norman SA, et al. For whom does it work? Moderators of the effects of written emotional disclosure in a randomized trial among women with chronic pelvic pain. Psychosom Med. 2004;66(2):174-83. X-3. [pmid: 15039501].
546 Geramoutsos I, et al. Clinical correlation of prostatic lithiasis with chronic pelvic pain syndromes in young adults. Eur Urol. 2004;45(3):333-7. discussion 337-8. X-2, X-3, X-4. [pmid: 15036679].
547 Nickel JC, et al. Treatment of chronic prostatitis/chronic pelvic pain syndrome with tamsulosin: a randomized double blind trial. J Urol. 2004;171(4):1594-7. X-2, X-3, X-4. [pmid: 15017228].
548 Elzawahri A, et al. Urinary conduit formation using a retubularized bowel from continent urinary diversion or intestinal augmentations: ii. Does it have a role in patients with interstitial cystitis?. J Urol. 2004;171(4):1559-62. X-3. [pmid: 15017220].
549 Paulis G, et al. Evaluation of the cytokines in genital secretions of patients with chronic prostatitis. Arch Ital Urol Androl. 2003;75(4):179-86. X-2, X-3, X-4. [pmid: 15005490].
550 Carta G, Cerrone L, Iovenitti P. Postoperative adhesion prevention in gynecologic surgery with hyaluronic acid. Clin Exp Obstet Gynecol. 2004;31(1):39-41. X-3, X-4. [pmid: 14998185].
551 Croak AJ, et al. Characteristics of patients with vaginal rupture and evisceration. Obstet Gynecol. 2004;103(3):572-6. X-2, X-3, X-4. [pmid: 14990423].
552 Dobie DJ, et al. Posttraumatic stress disorder in female veterans: association with self-reported health problems and functional impairment. Arch Intern Med. 2004;164(4):394-400. X-2, X-3, X-4, X-5. [pmid: 14980990].
553 Park SJ, et al. Diagnosis of pelvic congestion syndrome using transabdominal and transvaginal sonography. AJR Am J Roentgenol. 2004;182(3):683-8. X-3, X-4, X-5. [pmid: 14975970].
554 Pavkov ML, et al. Quantitative evaluation of the utero-ovarian venous pattern in the adult human female cadaver with plastination. World J Surg. 2004;28(2):201-5. X-2, X-3, X-4. [pmid: 14973766].
555 Ailawadi RK, et al. Treatment of endometriosis and chronic pelvic pain with letrozole and norethindrone acetate: a pilot study. Fertil Steril. 2004;81(2):290-6. X-3. [pmid: 14967362].
556 Dogan E, et al. Anesthetic effect of intrauterine lidocaine plus naproxen sodium in endometrial biopsy. Obstet Gynecol. 2004;103(2):347-51. X-2, X-3, X-4, X-5. [pmid: 14754707].
557 Keay S, et al. Antiproliferative factor, heparin-binding epidermal growth factor-like growth factor, and epidermal growth factor in men with interstitial cystitis versus chronic pelvic pain syndrome. Urology. 2004;63(1):22-6. X-2, X-3, X-4. [pmid: 14751340].
558 De Rose AF, et al. Role of mepartricin in category III chronic nonbacterial prostatitis/chronic pelvic pain syndrome: a randomized prospective placebo-controlled trial. Urology. 2004;63(1):13-6. X-2, X-3, X-4. [pmid: 14751338].
559 Fagotti A, et al. Analysis of cyclooxygenase-2 (COX-2) expression in different sites of endometriosis and correlation with clinico-pathological parameters. Hum Reprod. 2004;19(2):393-7. X-3, X-4, X-5. [pmid: 14747187].
560 Roberts RO, et al. Prostatitis as a risk factor for prostate cancer. Epidemiology. 2004;15(1):93-9. X-2, X-3, X-4. [pmid: 14712152].
561 Chiang PH, Chiang CP. Therapeutic effect of transurethral needle ablation in non-bacterial prostatitis: chronic pelvic pain syndrome type IIIa. Int J Urol. 2004;11(2):97-102. X-2, X-3, X-4. [pmid: 14706013].
562 Bachar GN, et al. Initial experience with ovarian vein embolization for the treatment of chronic pelvic pain syndrome. Isr Med Assoc J. 2003;5(12):843-6. X-3. [pmid: 14689749].
563 Hawkins RS, Hart AD. The use of thermal biofeedback in the treatment of pain associated with endometriosis: preliminary findings. Appl Psychophysiol Biofeedback. 2003;28(4):279-89. X-3. [pmid: 14686081].
564 Baxter N, Black J, Duffy S. The effect of a gonadotrophin-releasing hormone analogue as first-line management in cyclical pelvic pain. J Obstet Gynaecol. 2004;24(1):64-6. X-2, X-3, X-4, X-5. [pmid: 14675984].
565 Haggerty CL, Schulz R, Ness RB. Lower quality of life among women with chronic pelvic pain after pelvic inflammatory disease. Obstet Gynecol. 2003;102(5 Pt 1):934-9. X-3, X-4, X-5. [pmid: 14672466].
566 Lippman SA, et al. Uterine fibroids and gynecologic pain symptoms in a population-based study. Fertil Steril. 2003;80(6):1488-94. X-2, X-3, X-4, X-5. [pmid: 14667888].
567 Kaplan SA, Volpe MA, Te AE. A prospective, 1-year trial using saw palmetto versus finasteride in the treatment of category III prostatitis/chronic pelvic pain syndrome. J Urol. 2004;171(1):284-8. X-2, X-3, X-4. [pmid: 14665895].
568 Diokno AC, et al. Interstitial cystitis, gynecologic pelvic pain, prostatitis, and their epidemiology. Int J Urol. 2003;10(Suppl):S3-6. X-1, X-2, X-3, X-4. [pmid: 14641405].
569 Birtle AJ, et al. Clinical features of patients who present with metastatic prostate carcinoma and serum prostate-specific antigen (PSA) levels < 10 ng/mL: the “PSA negative” patients. Cancer. 2003;98(11):2362-7. X-2, X-3, X-4. [pmid: 14635070].
570 Kiyota H, et al. Questionnaire survey of Japanese urologists concerning the diagnosis and treatment of chronic prostatitis and chronic pelvic pain syndrome. Int J Urol. 2003;10(12):636-42. X-2, X-3, X-4. [pmid: 14633066].
571 Rizzo M, et al. Prevalence, diagnosis and treatment of prostatitis in Italy: a prospective urology outpatient practice study. BJU Int. 2003;92(9):955-9. X-2, X-3, X-4. [pmid: 14632854].
572 Engeler DS, Hauri D, John H. Impact of prostatitis NIH IIIB (prostatodynia) on ejaculate parameters. Eur Urol. 2003;44(5):546-8. X-2, X-3, X-4. [pmid: 14572752].
573 Lyons TL, Adolph AJ, Winer WK. Ovarian remnant with bilateral duplicate ureters. J Am Assoc Gynecol Laparosc. 2003;10(3):407-8. X-3. [pmid: 14567824].
574 Exacoustos C, et al. Hysterosalpingo-contrast sonography compared with hysterosalpingography and laparoscopic dye pertubation to evaluate tubal patency. J Am Assoc Gynecol Laparosc. 2003;10(3):367-72. X-3, X-4. [pmid: 14567814].
575 Newman C, Finan MA. Hysterectomy in women with cervical stenosis. Surgical indications and pathology. J Reprod Med. 2003;48(9):672-6. X-3. [pmid: 14562629].
576 Parazzini F. Left:right side ratio of endometriotic implants in the pelvis. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):65-7. X-2, X-3, X-4, X-5. [pmid: 14557014].
577 Nickel JC, et al. Levofloxacin for chronic prostatitis/chronic pelvic pain syndrome in men: a randomized placebo-controlled multicenter trial. Urology. 2003;62(4):614-7. X-2, X-3, X-4. [pmid: 14550427].
578 John H, et al. Immunological alterations in the ejaculate of chronic prostatitis patients: clues for autoimmunity. Andrologia. 2003;35(5):294-9. X-2, X-3, X-4. [pmid: 14535858].
579 Menkveld R, et al. Morphological sperm alternations in different types of prostatitis. Andrologia. 2003;35(5):288-93. X-2, X-3, X-4. [pmid: 14535857].
580 Punab M, et al. The limit of leucocytospermia from the microbiological viewpoint. Andrologia. 2003;35(5):271-8. X-2, X-3, X-4. [pmid: 14535854].
581 Krieger JN, et al. Seminal fluid analysis in chronic prostatitis/chronic pelvic pain syndrome. Andrologia. 2003;35(5):266-70. X-2, X-3, X-4. [pmid: 14535853].
582 Badalyan RR, Fanarjyan SV, Aghajanyan IG. Chlamydial and ureaplasmal infections in patients with nonbacterial chronic prostatitis. Andrologia. 2003;35(5):263-5. X-2, X-3, X-4. [pmid: 14535852].
583 Schneider H, et al. The 2001 Giessen Cohort Study on patients with prostatitis syndrome--an evaluation of inflammatory status and search for microorganisms 10 years after a first analysis. Andrologia. 2003;35(5):258-62. X-2, X-3, X-4. [pmid: 14535851].
584 Kamat AM, et al. Total pelvic exenteration: effective palliation of perineal pain in patients with locally recurrent prostate cancer. J Urol. 2003;170(5):1868-71. X-2, X-3, X-4. [pmid: 14532795].
585 John H, et al. A new high frequency electrostimulation device to treat chronic prostatitis. J Urol. 2003;170(4 Pt 1):1275-7. X-2, X-3, X-4. [pmid: 14501740].
586 Fitzwater JB, Kuehl TJ, Schrier JJ. Electrical stimulation in the treatment of pelvic pain due to levator ani spasm. J Reprod Med. 2003;48(8):573-7. X-3. [pmid: 12971135].
587 Vercellini P, et al. Continuous use of an oral contraceptive for endometriosis-associated recurrent dysmenorrhea that does not respond to a cyclic pill regimen. Fertil Steril. 2003;80(3):560-3. X-3, X-4. [pmid: 12969698].
588 Mehik A, et al. Alfuzosin treatment for chronic prostatitis/chronic pelvic pain syndrome: a prospective, randomized, double-blind, placebo-controlled, pilot study. Urology. 2003;62(3):425-9. X-2, X-3, X-4. [pmid: 12946740].
589 Ryu JK, et al. Tc-99m ciprofloxacin imaging in diagnosis of chronic bacterial prostatitis. Asian J Androl. 2003;5(3):179-83. X-2, X-3, X-4. [pmid: 12937798].
590 Bunyavejchevin S, et al. Laparoscopic finding in Thai women with chronic pelvic pain. J Med Assoc Thai. Suppl 2. 2003;86:S404-8. X-3, X-4, X-5. [pmid: 12930017].
591 Wanebo HJ, et al. Isolated chemotherapeutic perfusion of the pelvis for advanced rectal cancer. Colorectal Dis. 2003;5(5):508-14. X-2, X-3, X-4. [pmid: 12925091].
592 Abbott JA, et al. The effects and effectiveness of laparoscopic excision of endometriosis: a prospective study with 2-5 year follow-up. Hum Reprod. 2003;18(9):1922-7. X-4. [pmid: 12923150].
593 Yeh JM, Hook EW 3rd, Goldie SJ. A refined estimate of the average lifetime cost of pelvic inflammatory disease. Sex Transm Dis. 2003;30(5):369-78. X-4. [pmid: 12916126].
594 Hetrick DC, et al. Musculoskeletal dysfunction in men with chronic pelvic pain syndrome type III: a case-control study. J Urol. 2003;170(3):828-31. X-2, X-3, X-4. [pmid: 12913709].
595 Yang CC, et al. Pain sensitization in male chronic pelvic pain syndrome: why are symptoms so difficult to treat?. J Urol. 2003;170(3):823-6. discussion 826-7. X-2, X-3, X-4. [pmid: 12913708].
596 Nickel JC, et al. Leukocytes and bacteria in men with chronic prostatitis/chronic pelvic pain syndrome compared to asymptomatic controls. J Urol. 2003;170(3):818-22. X-2, X-3, X-4. [pmid: 12913707].
597 Vercellini P, et al. Laparoscopic uterosacral ligament resection for dysmenorrhea associated with endometriosis: results of a randomized, controlled trial. Fertil Steril. 2003;80(2):310-9. X-3, X-4. [pmid: 12909493].
598 Vercellini P, et al. Comparison of a levonorgestrel-releasing intrauterine device versus expectant management after conservative surgery for symptomatic endometriosis: a pilot study. Fertil Steril. 2003;80(2):305-9. X-3, X-4. [pmid: 12909492].
599 Halperin R, et al. Long-term follow-up (5-20 years) after uterine ventrosuspension for chronic pelvic pain and deep dyspareunia. Gynecol Obstet Invest. 2003;55(4):216-9. X-3, X-4, X-5. [pmid: 12904695].
600 Leskinen MJ, et al. The Finnish version of The National Institutes Of Health Chronic Prostatitis Symptom Index correlates well with the visual pain scale: translation and results of a modified linguistic validation study. BJU Int. 2003;92(3):251-6. X-2, X-3, X-4. [pmid: 12887478].
601 Zullo F, et al. Effectiveness of presacral neurectomy in women with severe dysmenorrhea caused by endometriosis who were treated with laparoscopic conservative surgery: a 1-year prospective randomized double-blind controlled trial. Am J Obstet Gynecol. 2003;189(1):5-10. X-2, X-3. [pmid: 12861130].
602 Tanaka T. A novel anti-dysmenorrhea therapy with cyclic administration of two Japanese herbal medicines. Clin Exp Obstet Gynecol. 2003;30(2-3):95-8. X-3. [pmid: 12854851].
603 Nijenhuis ER, et al. Evidence for associations among somatoform dissociation, psychological dissociation and reported trauma in patients with chronic pelvic pain. J Psychosom Obstet Gynaecol. 2003;24(2):87-98. X-2, X-3, X-4. [pmid: 12854393].
604 Dhillon PK, Holt VL. Recreational physical activity and endometrioma risk. Am J Epidemiol. 2003;158(2):156-64. X-2, X-3, X-4, X-5. [pmid: 12851229].
605 Krieger JN. Prostatitis revisited: new definitions, new approaches. Infect Dis Clin North Am. 2003;17(2):395-409. X-1, X-2, X-3, X-4. [pmid: 12848476].
606 Krieger JN, et al. Counting leukocytes in expressed prostatic secretions from patients with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2003;62(1):30-4. X-2, X-3, X-4. [pmid: 12837417].
607 Hruz P, et al. Non-inflammatory chronic pelvic pain syndrome can be caused by bladder neck hypertrophy. Eur Urol. 2003;44(1):106-10. discussion 110. X-2, X-3, X-4. [pmid: 12814683].
608 Chen R, Nickel JC. Acupuncture ameliorates symptoms in men with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2003;61(6):1156-9. discussion 1159. X-2, X-3, X-4. [pmid: 12809886].
609 Ozalp S, et al. Microvessel density (MVD) as a prognosticator in endometrial carcinoma. Eur J Gynaecol Oncol. 2003;24(3-4):305-8. X-2, X-3, X-4, X-5. [pmid: 12807245].
610 Husby GK, Haugen RS, Moen MH. Diagnostic delay in women with pain and endometriosis. Acta Obstet Gynecol Scand. 2003;82(7):649-53. X-3, X-4, X-5. [pmid: 12790847].
611 Blanco RG, et al. Abdominal wall endometriomas. Am J Surg. 2003;185(6):596-8. X-3, X-4. [pmid: 12781893].
612 Nickel JC. Classification and diagnosis of prostatitis: a gold standard?. Andrologia. 2003;35(3):160-7. X-1, X-2, X-3, X-4. [pmid: 12780534].
613 Ludwig M, et al. Significance of inflammation on standard semen analysis in chronic prostatitis/chronic pelvic pain syndrome. Andrologia. 2003;35(3):152-6. X-2, X-3, X-4. [pmid: 12780532].
614 Ye ZQ, et al. Biofeedback therapy for chronic pelvic pain syndrome. Asian J Androl. 2003;5(2):155-8. X-2, X-3, X-4, X-5. [pmid: 12778328].
615 Schneider H, et al. Experience with different questionnaires in the management of patients with CP/CPPS: GPSS, IPSS and NIH-CPSI. World J Urol. 2003;21(3):116-8. discussion 115. X-2, X-3, X-4. [pmid: 12768318].
616 Harlow BL, Stewart EG. A population-based assessment of chronic unexplained vulvar pain: have we underestimated the prevalence of vulvodynia?. J Am Med Womens Assoc. 2003;58(2):82-8. X-2, X-3, X-4, X-5. [pmid: 12744420].
617 Takahashi S, Riley DE, Krieger JN. Application of real-time polymerase chain reaction technology to detect prostatic bacteria in patients with chronic prostatitis/chronic pelvic pain syndrome. World J Urol. 2003;21(2):100-4. X-2, X-3, X-4. [pmid: 12743735].
618 Jones KD, Sutton C. Patient satisfaction and changes in pain scores after ablative laparoscopic surgery for stage III-IV endometriosis and endometriotic cysts. Fertil Steril. 2003;79(5):1086-90. X-2, X-3. [pmid: 12738500].
619 Hollett-Caines J, Vilos GA, Penava DA. Laparoscopic mobilization of the rectosigmoid and excision of the obliterated cul-de-sac. J Am Assoc Gynecol Laparosc. 2003;10(2):190-4. X-3. [pmid: 12732770].
620 Agarwala N, Liu CY. Laparoscopic appendectomy. J Am Assoc Gynecol Laparosc. 2003;10(2):166-8. X-2, X-3, X-4. [pmid: 12732765].
621 Pieri S, et al. Percutaneous treatment of pelvic congestion syndrome. Radiol Med. 2003;105(1-2):76-82. X-3. [pmid: 12700549].
622 Spandorfer SD, Barnhart KT. Role of previous ectopic pregnancy in altering the presentation of suspected ectopic pregnancy. J Reprod Med. 2003;48(3):133-6. X-2, X-3, X-4. [pmid: 12698768].
623 Ludwig M, et al. Chronic prostatitis/chronic pelvic pain pyndrome): seminal markers of inflammation. World J Urol. 2003;21(2):82-5. X-2, X-3, X-4. [pmid: 12690515].
624 Lampe A, et al. Chronic pain syndromes and their relation to childhood abuse and stressful life events. J Psychosom Res. 2003;54(4):361-7. X-3. [pmid: 12670615].
625 Leskinen MJ, et al. Negative bacterial polymerase chain reaction (PCR) findings in prostate tissue from patients with symptoms of chronic pelvic pain syndrome (CPPS) and localized prostate cancer. Prostate. 2003;55(2):105-10. X-2, X-3, X-4. [pmid: 12661035].
626 van Os-Bossagh P, et al. Voiding symptoms in chronic pelvic pain (CPP). Eur J Obstet Gynecol Reprod Biol. 2003;107(2):185-90. X-4. [pmid: 12648866].
627 Fox SD. Chronic pelvic pain in women. Med Health R I. 2003;86(1):9-11. X-1, X-2, X-3, X-4, X-5. [pmid: 12633014].
628 Shoskes DA, et al. Long-term results of multimodal therapy for chronic prostatitis/chronic pelvic pain syndrome. J Urol. 2003;169(4):1406-10. X-2, X-3, X-4. [pmid: 12629373].
629 Nickel JC, et al. A randomized, placebo controlled, multicenter study to evaluate the safety and efficacy of rofecoxib in the treatment of chronic nonbacterial prostatitis. J Urol. 2003;169(4):1401-5. X-2, X-3, X-4. [pmid: 12629372].
630 Leskinen MJ, et al. Herpes simplex virus, cytomegalovirus, and papillomavirus DNA are not found in patients with chronic pelvic pain syndrome undergoing radical prostatectomy for localized prostate cancer. Urology. 2003;61(2):397-401. X-2, X-3, X-4. [pmid: 12597955].
631 van Balken MR, et al. Percutaneous tibial nerve stimulation as neuromodulative treatment of chronic pelvic pain. Eur Urol. 2003;43(2):158-63. discussion 163. X-3. [pmid: 12565774].
632 Cheah PY, et al. Chronic prostatitis: symptom survey with follow-up clinical evaluation. Urology. 2003;61(1):60-4. X-2, X-3, X-4. [pmid: 12559266].
633 Abu-Rafeh B, Vilos GA, Misra M. Frequency and laparoscopic management of ovarian remnant syndrome. J Am Assoc Gynecol Laparosc. 2003;10(1):33-7. X-2, X-3, X-4. [pmid: 12554991].
634 Ulrich YC, et al. Medical care utilization patterns in women with diagnosed domestic violence. Am J Prev Med. 2003;24(1):9-15. X-4. [pmid: 12554018].
635 Haggerty CL, et al. Endometritis does not predict reproductive morbidity after pelvic inflammatory disease. Am J Obstet Gynecol. 2003;188(1):141-8. X-2, X-3, X-4, X-5. [pmid: 12548208].
636 Cheah PY, et al. Terazosin therapy for chronic prostatitis/chronic pelvic pain syndrome: a randomized, placebo controlled trial. J Urol. 2003;169(2):592-6. X-2, X-3, X-4. [pmid: 12544314].
637 Lee JC, et al. Prostate biopsy culture findings of men with chronic pelvic pain syndrome do not differ from those of healthy controls. J Urol. 2003;169(2):584-7. discussion 587-8. X-2, X-3, X-4. [pmid: 12544312].
638 Turner JA, et al. Validity and responsiveness of the national institutes of health chronic prostatitis symptom index. J Urol. 2003;169(2):580-3. X-2, X-3, X-4. [pmid: 12544311].
639 Schillinger JA, et al. Patient-delivered partner treatment with azithromycin to prevent repeated Chlamydia trachomatis infection among women: a randomized, controlled trial. Sex Transm Dis. 2003;30(1):49-56. X-2, X-3, X-4, X-5. [pmid: 12514443].
640 Brown CS, et al. Efficacy of static magnetic field therapy in chronic pelvic pain: a double-blind pilot study. Am J Obstet Gynecol. 2002;187(6):1581-7. X-3. [pmid: 12501067].
641 Quinn MJ, Kirk N. Differences in uterine innervation at hysterectomy. Am J Obstet Gynecol. 2002;187(6):1515. discussion 1519-20. X-3. [pmid: 12501055].
642 Chung MK, et al. The evil twins of chronic pelvic pain syndrome: endometriosis and interstitial cystitis. JSLS. 2002;6(4):311-4. X-3. [pmid: 12500828].
643 Vega RE. Distal urethral web: a risk factor in prostatitis. Prostate Cancer Prostatic Dis. 2002;5(3):180-2. X-1, X-2, X-3, X-4. [pmid: 12496978].
644 Krieger JN, et al. Symptoms and inflammation in chronic prostatitis/chronic pelvic pain syndrome. Urology. 2002;60(6):959-63. X-2, X-3, X-4. [pmid: 12475649].
645 Chandler B, et al. To leave or not to leave? A retrospective review of appendectomy during diagnostic laparoscopy for chronic pelvic pain. Mo Med. 2002;99(9):502-4. X-3. [pmid: 12462943].
646 Moore J, Ziebland S, Kennedy S. “People sometimes react funny if they're not told enough”: women's views about the risks of diagnostic laparoscopy. Health Expect. 2002;5(4):302-9. X-3, X-4. [pmid: 12460219].
647 Sharma JB, Malhotra M, Arora R. Incidential Fitz-Hugh-Curtis syndrome at laparoscopy for benign gynecologic conditions. Int J Gynaecol Obstet. 2002;79(3):237-40. X-2, X-3, X-4, X-5. [pmid: 12445989].
648 Yoshida S, et al. Laparoscopic surgery for the management of ovarian endometrioma. Gynecol Obstet Invest. Suppl 1. 2002;54:24-7. discussion 27-9. X-2, X-3, X-4, X-5. [pmid: 12441657].
649 Momoeda M, et al. Is endometriosis really associated with pain?. Gynecol Obstet Invest. Suppl 1. 2002;54:18-21. discussion 21-3. X-2, X-3, X-4. [pmid: 12441656].
650 Almeida EC, et al. Cesarean section as a cause of chronic pelvic pain. Int J Gynaecol Obstet. 2002;79(2):101-4. X-3, X-4, X-5. [pmid: 12427392].
651 Nickel JC, et al. Prostatitis-like symptoms: one year later. BJU Int. 2002;90(7):678-81. X-2, X-3, X-4. [pmid: 12410746].
652 Aboseif S, et al. Sacral neuromodulation in functional urinary retention: an effective way to restore voiding. BJU Int. 2002;90(7):662-5. X-3, X-4. [pmid: 12410743].
653 Esnaola NF, et al. Pain and quality of life after treatment in patients with locally recurrent rectal cancer. J Clin Oncol. 2002;20(21):4361-7. X-2, X-3, X-4. [pmid: 12409336].
654 Abbott J, et al. Pelvic pain scores in women without pelvic pathology. J Am Assoc Gynecol Laparosc. 2002;9(4):414-7. X-2, X-3, X-4, X-5. [pmid: 12386349].
655 Stratton P, et al. Location, color, size, depth, and volume may predict endometriosis in lesions resected at surgery. Fertil Steril. 2002;78(4):743-9. X-4. [pmid: 12372450].
656 Fauconnier A, et al. Relation between pain symptoms and the anatomic location of deep infiltrating endometriosis. Fertil Steril. 2002;78(4):719-26. X-2, X-3, X-4, X-5. [pmid: 12372446].
657 Antolak SJ Jr, et al. Anatomical basis of chronic pelvic pain syndrome: the ischial spine and pudendal nerve entrapment. Med Hypotheses. 2002;59(3):349-53. X-1, X-2, X-3, X-4, X-5. [pmid: 12208168].
658 Foong LC, et al. Microvascular changes in the peripheral microcirculation of women with chronic pelvic pain due to congestion. BJOG. 2002;109(8):867-73. X-3. [pmid: 12197365].
659 Schaeffer AJ, et al. Leukocyte and bacterial counts do not correlate with severity of symptoms in men with chronic prostatitis: the National Institutes of Health Chronic Prostatitis Cohort Study. J Urol. 2002;168(3):1048-53. X-2, X-3, X-4. [pmid: 12187220].
660 Belenky A, et al. Ovarian varices in healthy female kidney donors: incidence, morbidity, and clinical outcome. AJR Am J Roentgenol. 2002;179(3):625-7. X-3. [pmid: 12185031].
661 Taylor D, Miaskowski C, Kohn J. A randomized clinical trial of the effectiveness of an acupressure device (relief brief) for managing symptoms of dysmenorrhea. J Altern Complement Med. 2002;8(3):357-70. X-2, X-3, X-4. [pmid: 12165194].
662 Ghobish A. Voiding dysfunction associated with “chronic bacterial prostatitis”. Eur Urol. 2002;42(2):159-62. X-2, X-3, X-4. [pmid: 12160587].
663 Clemons JL, Arya LA, Myers DL. Diagnosing interstitial cystitis in women with chronic pelvic pain. Obstet Gynecol. 2002;100(2):337-41. X-2, X-3, X-5. [pmid: 12151160].
664 Shoskes DA. Phytotherapy and other alternative forms of care for the patient with prostatitis. Curr Urol Rep. 2002;3(4):330-4. X-1, X-2, X-3, X-4. [pmid: 12149166].
665 Krieger JN, et al. The NIH Consensus concept of chronic prostatitis/chronic pelvic pain syndrome compared with traditional concepts of nonbacterial prostatitis and prostatodynia. Curr Urol Rep. 2002;3(4):301-6. X-2, X-3, X-4. [pmid: 12149161].
666 Leskinen MJ, et al. Transurethral needle ablation for the treatment of chronic pelvic pain syndrome (category III prostatitis): a randomized, sham-controlled study. Urology. 2002;60(2):300-4. X-2, X-3, X-4. [pmid: 12137830].
667 Krieger JN, Riley DE. Prostatitis: what is the role of infection. Int J Antimicrob Agents. 2002;19(6):475-9. X-2, X-3, X-4. [pmid: 12135836].
668 Schaeffer AJ, et al. Demographic and clinical characteristics of men with chronic prostatitis: the national institutes of health chronic prostatitis cohort study. J Urol. 2002;168(2):593-8. X-2, X-3, X-4. [pmid: 12131316].
669 Ludwig M, et al. Seminal secretory capacity of the male accessory sex glands in chronic pelvic pain syndrome (CPPS)/chronic prostatitis with special focus on the new prostatitis classification. Eur Urol. 2002;42(1):24-8. X-2, X-3, X-4. [pmid: 12121725].
670 Yen CF, et al. Combined laparoscopic uterosacral and round ligament procedures for treatment of symptomatic uterine retroversion and mild uterine decensus. J Am Assoc Gynecol Laparosc. 2002;9(3):359-66. X-3. [pmid: 12101335].
671 Comino R, Torrejon R, Sanchez-Ortega I. Long-term results of endometrial ablation-resection. J Am Assoc Gynecol Laparosc. 2002;9(3):268-71. X-2, X-3, X-4, X-5. [pmid: 12101320].
672 Aboseif S, et al. Sacral neuromodulation as an effective treatment for refractory pelvic floor dysfunction. Urology. 2002;60(1):52-6. X-3, X-4. [pmid: 12100921].
673 van Os-Bossagh P, et al. Questionnaire as diagnostic tool in chronic pelvic pain (CPP): a pilot study. Eur J Obstet Gynecol Reprod Biol. 2002;103(2):173-8. X-3. [pmid: 12069743].
674 Lentz GM, et al. Hormonal manipulation in women with chronic, cyclic irritable bladder symptoms and pelvic pain. Am J Obstet Gynecol. 2002;186(6):1268-71. discussion 1271-3. X-3. [pmid: 12066108].
675 Shoskes DA, et al. Cytokine polymorphisms in men with chronic prostatitis/chronic pelvic pain syndrome: association with diagnosis and treatment response. J Urol. 2002;168(1):331-5. X-2, X-3, X-4. [pmid: 12050565].
676 Zhao D, Lebovic DI, Taylor RN. Long-term progestin treatment inhibits RANTES (regulated on activation, normal T cell expressed and secreted) gene expression in human endometrial stromal cells. J Clin Endocrinol Metab. 2002;87(6):2514-9. X-2, X-3, X-4. [pmid: 12050207].
677 Bajaj P, Madsen H, Arendt-Nielsen L. A comparison of modality-specific somatosensory changes during menstruation in dysmenorrheic and nondysmenorrheic women. Clin J Pain. 2002;18(3):180-90. X-2, X-3, X-4. [pmid: 12048420].
678 Batstone GR, Doble A, Gaston JS. Autoimmune T cell responses to seminal plasma in chronic pelvic pain syndrome (CPPS). Clin Exp Immunol. 2002;128(2):302-7. X-2, X-3, X-4. [pmid: 12041509].
679 Propert KJ, et al. Design of a multicenter randomized clinical trial for chronic prostatitis/chronic pelvic pain syndrome. Urology. 2002;59(6):870-6. X-1, X-2, X-3, X-4. [pmid: 12031372].
680 Romans S, et al. Childhood abuse and later medical disorders in women. An epidemiological study. Psychother Psychosom. 2002;71(3):141-50. X-2, X-3, X-4, X-5. [pmid: 12021556].
681 Campbell J, et al. Intimate partner violence and physical health consequences. Arch Intern Med. 2002;162(10):1157-63. X-2, X-3, X-4, X-5. [pmid: 12020187].
682 Ness RB, et al. Effectiveness of inpatient and outpatient treatment strategies for women with pelvic inflammatory disease: results from the Pelvic Inflammatory Disease Evaluation and Clinical Health (PEACH) Randomized Trial. Am J Obstet Gynecol. 2002;186(5):929-37. X-2, X-3, X-4. [pmid: 12015517].
683 Luzzi GA, et al. Chronic prostatitis/chronic pelvic pain syndrome: national survey of genitourinary medicine clinics. Int J STD AIDS. 2002;13(6):416-9. X-2, X-3, X-4. [pmid: 12015017].
684 Collopy BT, Barham KA. Abdominal colporectopexy with pelvic cul-de-sac closure. Dis Colon Rectum. 2002;45(4):522-6. discussion 526-9. X-2, X-3, X-5. [pmid: 12006935].
685 Nascimento AB, Mitchell DG, Holland G. Ovarian veins: magnetic resonance imaging findings in an asymptomatic population. J Magn Reson Imaging. 2002;15(5):551-6. X-2, X-3, X-4. [pmid: 11997896].
686 Metin A, Kayigil O, Ahmed SI. Modified insitu vaginal wall sling in stress incontinence. Int Urol Nephrol. 2001;32(4):641-5. X-3, X-4. [pmid: 11989556].
687 Vilos GA, Vilos AW, Haebe JJ. Laparoscopic findings, management, histopathology, and outcome of 25 women with cyclic leg pain. J Am Assoc Gynecol Laparosc. 2002;9(2):145-51. X-3. [pmid: 11960038].
688 Murphy AA. Clinical aspects of endometriosis. Ann N Y Acad Sci. 2002;955:1-10. discussion 34-6, 396-406. X-1, X-2, X-3. [pmid: 11949938].
689 Ghanem AN. Features and complications of nephroptosis causing the loin pain and hematuria syndrome. A preliminary report. Saudi Med J. 2002;23(2):197-205. X-2, X-4. [pmid: 11938398].
690 Ou CS, et al. Laparoscopic uterine suspension by round ligament plication. J Reprod Med. 2002;47(3):211-6. X-3. [pmid: 11933686].
691 Miller LJ, et al. Nerve growth factor and chronic prostatitis/chronic pelvic pain syndrome. Urology. 2002;59(4):603-8. X-2, X-3, X-4. [pmid: 11927336].
692 Turner JA, et al. Primary care and urology patients with the male pelvic pain syndrome: symptoms and quality of life. J Urol. 2002;167(4):1768-73. X-2, X-3, X-4. [pmid: 11912406].
693 Gray M, Albo M, Huffstutler S. Interstitial cystitis: a guide to recognition, evaluation, and management for nurse practitioners. J Wound Ostomy Continence Nurs. 2002;29(2):93-102. X-1, X-2, X-3, X-4. [pmid: 11901418].
694 Hawk C, et al. Issues in planning a placebo-controlled trial of manual methods: results of a pilot study. J Altern Complement Med. 2002;8(1):21-32. X-3. [pmid: 11890430].
695 Bai SW, et al. Endometriosis in an adolescent population: the severance hospital in Korean experience. Yonsei Med J. 2002;43(1):48-52. X-3. [pmid: 11854932].
696 Yamada T, et al. Polytetrafluoroethylene patch sling for type 2 or type 3 stress urinary incontinence. Int J Urol. 2001;8(12):675-80. X-2, X-3, X-4. [pmid: 11851767].
697 Venbrux AC, et al. Pelvic congestion syndrome (pelvic venous incompetence): impact of ovarian and internal iliac vein embolotherapy on menstrual cycle and chronic pelvic pain. J Vasc Interv Radiol. 2002;13(2 Pt 1):171-8. X-3. [pmid: 11830623].
698 Miller LJ, et al. Interleukin-10 levels in seminal plasma: implications for chronic prostatitis-chronic pelvic pain syndrome. J Urol. 2002;167(2 Pt 1):753-6. X-2, X-3, X-4. [pmid: 11792966].
699 Riley DE, Krieger JN. X Chromosomal short tandem repeat polymorphisms near the phosphoglycerate kinase gene in men with chronic prostatitis. Biochim Biophys Acta. 2002;1586(1):99-107. X-2, X-3, X-4. [pmid: 11781154].
700 Vercellini P, et al. Cyproterone acetate versus a continuous monophasic oral contraceptive in the treatment of recurrent pelvic pain after conservative surgery for symptomatic endometriosis. Fertil Steril. 2002;77(1):52-61. X-3. [pmid: 11779591].
701 Heit M, et al. Is pelvic organ prolapse a cause of pelvic or low back pain?. Obstet Gynecol. 2002;99(1):23-8. X-2, X-3, X-4, X-5. [pmid: 11777505].
702 Mehik A, et al. The chronic prostatitis-chronic pelvic pain syndrome can be characterized by prostatic tissue pressure measurements. J Urol. 2002;167(1):137-40. X-2, X-3, X-4. [pmid: 11743292].
703 Bulletti C, et al. Endometriosis: absence of recurrence in patients after endometrial ablation. Hum Reprod. 2001;16(12):2676-9. X-3, X-4. [pmid: 11726595].
704 Eskenazi B, et al. Validation study of nonsurgical diagnosis of endometriosis. Fertil Steril. 2001;76(5):929-35. X-2, X-3, X-4, X-5. [pmid: 11704113].
705 Okaro EO, Jones KD, Sutton C. Long term outcome following laparoscopic supracervical hysterectomy. BJOG. 2001;108(10):1017-20. X-2, X-3, X-4, X-5. [pmid: 11702830].
706 Scultetus AH, Villavicencio JL, Gillespie DL. The nutcracker syndrome: its role in the pelvic venous disorders. J Vasc Surg. 2001;34(5):812-9. X-2, X-3, X-4. [pmid: 11700480].
707 Muller CH, et al. Comparison of microscopic methods for detecting inflammation in expressed prostatic secretions. J Urol. 2001;166(6):2518-24. X-2, X-3, X-4. [pmid: 11696821].
708 Driscoll A, Teichman JM. How do patients with interstitial cystitis present?. J Urol. 2001;166(6):2118-20. X-3. [pmid: 11696718].
709 Orhan I, et al. Seminal plasma cytokine levels in the diagnosis of chronic pelvic pain syndrome. Int J Urol. 2001;8(9):495-9. X-2, X-3, X-4. [pmid: 11683970].
710 Busacca M, et al. Post-operative GnRH analogue treatment after conservative surgery for symptomatic endometriosis stage III-IV: a randomized controlled trial. Hum Reprod. 2001;16(11):2399-402. X-3. [pmid: 11679528].
711 Li LJ, et al. The value of endotoxin concentrations in expressed prostatic secretions for the diagnosis and classification of chronic prostatitis. BJU Int. 2001;88(6):536-9. X-2, X-3, X-4. [pmid: 11678746].
712 Lyons TL, Winer WK, Woo A. Appendectomy in patients undergoing laparoscopic surgery for pelvic pain. J Am Assoc Gynecol Laparosc. 2001;8(4):542-4. X-2. [pmid: 11677334].
713 Roth RS, Punch MR, Bachman JE. Educational achievement and pain disability among women with chronic pelvic pain. J Psychosom Res. 2001;51(4):563-9. X-2, X-3, X-4, X-5. [pmid: 11595244].
714 Gowri V, Krolikowski A. Chronic pelvic pain. Laparoscopic and cystoscopic findings. Saudi Med J. 2001;22(9):769-70. X-3, X-4, X-5. [pmid: 11590449].
715 Siegel S, et al. Sacral nerve stimulation in patients with chronic intractable pelvic pain. J Urol. 2001;166(5):1742-5. X-3. [pmid: 11586214].
716 Shahed AR, Shoskes DA. Correlation of beta-endorphin and prostaglandin E2 levels in prostatic fluid of patients with chronic prostatitis with diagnosis and treatment response. J Urol. 2001;166(5):1738-41. X-2, X-3, X-4. [pmid: 11586213].
717 Gul O, Eroglu M, Ozok U. Use of terazosine in patients with chronic pelvic pain syndrome and evaluation by prostatitis symptom score index. Int Urol Nephrol. 2001;32(3):433-6. X-2, X-3, X-4. [pmid: 11583367].
718 Choktanasiri W, Rojanasakul A. Buserelin acetate implants in the treatment of pain in endometriosis. J Med Assoc Thai. 2001;84(5):656-60. X-3. [pmid: 11560214].
719 Sulaiman H, et al. Presence and distribution of sensory nerve fibers in human peritoneal adhesions. Ann Surg. 2001;234(2):256-61. X-3, X-4. [pmid: 11505072].
720 Lee JC, et al. Neurophysiologic testing in chronic pelvic pain syndrome: a pilot study. Urology. 2001;58(2):246-50. X-2, X-3, X-4. [pmid: 11489711].
721 Stones RW, Bradbury L, Anderson D. Randomized placebo controlled trial of lofexidine hydrochloride for chronic pelvic pain in women. Hum Reprod. 2001;16(8):1719-21. X-3. [pmid: 11473971].
722 Messelink EJ. The pelvic pain centre. World J Urol. 2001;19(3):208-12. X-1, X-2, X-3. [pmid: 11469609].
723 van Valkengoed IG, et al. Cost effectiveness analysis of a population based screening programme for asymptomatic Chlamydia trachomatis infections in women by means of home obtained urine specimens. Sex Transm Infect. 2001;77(4):276-82. X-2, X-3, X-4. [pmid: 11463928].
724 Zondervan KT, et al. The community prevalence of chronic pelvic pain in women and associated illness behaviour. Br J Gen Pract. 2001;51(468):541-7. X-4. [pmid: 11462313].
725 Regidor PA, et al. Prospective randomized study comparing the GnRH-agonist leuprorelin acetate and the gestagen lynestrenol in the treatment of severe endometriosis. Gynecol Endocrinol. 2001;15(3):202-9. X-3. [pmid: 11447732].
726 Ikonen S, et al. Prostatic MR imaging. Accuracy in differentiating cancer from other prostatic disorders. Acta Radiol. 2001;42(4):348-54. X-2, X-3, X-4. [pmid: 11442457].
727 Parsons CL, et al. Gynecologic presentation of interstitial cystitis as detected by intravesical potassium sensitivity. Obstet Gynecol. 2001;98(1):127-32. X-2, X-3, X-4, X-5. [pmid: 11430970].
728 Aaltomaa S, Ala-Opas M. The effect of transurethral needle ablation on symptoms of chronic pelvic pain syndrome--a pilot study. Scand J Urol Nephrol. 2001;35(2):127-31. X-2, X-3, X-4. [pmid: 11411655].
729 Walter AJ, et al. Endometriosis: correlation between histologic and visual findings at laparoscopy. Am J Obstet Gynecol. 2001;184(7):1407-11. discussion 1411-3. X-3, X-4. [pmid: 11408860].
730 Dilek ON, et al. Prophylactic appendectomy: is it worth to be done?. Acta Chir Belg. 2001;101(2):65-7. X-2, X-3, X-4, X-5. [pmid: 11396053].
731 Jones KD, Haines P, Sutton CJ. Long-term follow-up of a controlled trial of laser laparoscopy for pelvic pain. JSLS. 2001;5(2):111-5. X-3. [pmid: 11394422].
732 Wesselmann U. Interstitial cystitis: a chronic visceral pain syndrome. Urology. 2001;57(6 Suppl 1):102. X-1, X-2, X-3, X-4, X-5. [pmid: 11378059].
733 Sant GR, Hanno PM. Interstitial cystitis: current issues and controversies in diagnosis. Urology. 2001;57(6 Suppl 1):82-8. X-1, X-2, X-3, X-4. [pmid: 11378054].
734 Keay SK, et al. Sensitivity and specificity of antiproliferative factor, heparin-binding epidermal growth factor-like growth factor, and epidermal growth factor as urine markers for interstitial cystitis. Urology. 2001;57(6 Suppl 1):9-14. X-2, X-3, X-4, X-5. [pmid: 11378043].
735 Van Os-Bossagh P, et al. Micromotions of bladder wall in chronic pelvic pain (CPP): a pilot study. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):89-96. X-3, X-4. [pmid: 11374519].
736 Nickel JC, et al. Predictors of patient response to antibiotic therapy for the chronic prostatitis/chronic pelvic pain syndrome: a prospective multicenter clinical trial. J Urol. 2001;165(5):1539-44. X-2, X-3, X-4. [pmid: 11342913].
737 Wortman M, Daggett A. Reoperative hysteroscopic surgery in the management of patients who fail endometrial ablation and resection. J Am Assoc Gynecol Laparosc. 2001;8(2):272-7. X-2, X-3, X-4. [pmid: 11342737].
738 Soysal ME, et al. A randomized controlled trial of goserelin and medroxyprogesterone acetate in the treatment of pelvic congestion. Hum Reprod. 2001;16(5):931-9. X-3. [pmid: 11331640].
739 Dale A, et al. Management of chronic prostatitis in Genitourinary Medicine clinics in the United Kingdom's North Thames Region 2000. Int J STD AIDS. 2001;12(4):256-9. X-2, X-3, X-4. [pmid: 11319977].
740 Everaert K, et al. The pain cycle: implications for the diagnosis and treatment of pelvic pain syndromes. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(1):9-14. X-2, X-3. [pmid: 11294536].
741 Ludwig M, et al. Immunocytological analysis of leukocyte subpopulations in urine specimens before and after prostatic massage. Eur Urol. 2001;39(3):277-82. X-2, X-3, X-4. [pmid: 11275719].
742 Katske F, et al. Treatment of interstitial cystitis with a quercetin supplement. Tech Urol. 2001;7(1):44-6. X-3. [pmid: 11272677].
743 Chapron C, et al. Laparoscopically assisted vaginal management of deep endometriosis infiltrating the rectovaginal septum. Acta Obstet Gynecol Scand. 2001;80(4):349-54. X-3. [pmid: 11264611].
744 Aaron LA, et al. Comorbid clinical conditions in chronic fatigue: a co-twin control study. J Gen Intern Med. 2001;16(1):24-31. X-2, X-3, X-4, X-5. [pmid: 11251747].
745 Mayher BE, Guyton JL, Gingrich JR. Impact of urethral injury management on the treatment and outcome of concurrent pelvic fractures. Urology. 2001;57(3):439-42. X-2, X-3, X-4, X-5. [pmid: 11248615].
746 Taylor D. More than personal change: effective elements of symptom management. Nurse Pract Forum. 2000;11(2):79-86. X-2, X-3, X-4. [pmid: 11220058].
747 Whiteside JL, et al. Risks and adverse outcomes of sexually transmitted diseases. Patients' attitudes and beliefs. J Reprod Med. 2001;46(1):34-8. X-2, X-3, X-4. [pmid: 11209629].
748 John H, et al. Noninflammatory chronic pelvic pain syndrome: immunological study in blood, ejaculate and prostate tissue. Eur Urol. 2001;39(1):72-8. X-2, X-3, X-4. [pmid: 11173942].
749 Tulandi T, Felemban A, Chen MF. Nerve fibers and histopathology of endometriosis-harboring peritoneum. J Am Assoc Gynecol Laparosc. 2001;8(1):95-8. X-3, X-4. [pmid: 11172122].
750 Mehik A, et al. Prostatic tissue pressure measurement as a possible diagnostic procedure in patients with chronic nonbacterial prostatitis/chronic pelvic pain syndrome. Urol Res. 2000;28(5):316-8. X-2, X-3, X-4. [pmid: 11127709].
751 Halligan S, et al. Transvaginal ultrasound examination of women with and without pelvic venous congestion. Clin Radiol. 2000;55(12):954-8. X-3, X-4. [pmid: 11124075].
752 Donnez J, et al. Bladder endometriosis must be considered as bladder adenomyosis. Fertil Steril. 2000;74(6):1175-81. X-3, X-4. [pmid: 11119746].
753 Howard FM, El-Minawi AM, Sanchez RA. Conscious pain mapping by laparoscopy in women with chronic pelvic pain. Obstet Gynecol. 2000;96(6):934-9. X-3, X-4, X-5. [pmid: 11084181].
754 Lampe A, et al. Chronic pelvic pain and previous sexual abuse. Obstet Gynecol. 2000;96(6):929-33. X-3, X-4. [pmid: 11084180].
755 Johnson RA. Diagnosis and treatment of common sexually transmitted diseases in women. Clin Cornerstone. 2000;3(1):1-11. X-1, X-2, X-3, X-4. [pmid: 11061063].
756 Wu D, et al. Metabolic gene polymorphisms and risk of dysmenorrhea. Epidemiology. 2000;11(6):648-53. X-2, X-3, X-4. [pmid: 11055624].
757 Nezhat FR, et al. Laparoscopic adhesiolysis and relief of chronic pelvic pain. JSLS. 2000;4(4):281-5. X-3. [pmid: 11051185].
758 Batioglu S, Zeyneloglu HB. Laparoscopic plication and suspension of the round ligament for chronic pelvic pain and dyspareunia. J Am Assoc Gynecol Laparosc. 2000;7(4):547-51. X-3. [pmid: 11044511].
759 Welte R, et al. Cost-effectiveness of screening programs for Chlamydia trachomatis: a population-based dynamic approach. Sex Transm Dis. 2000;27(9):518-29. X-2, X-3, X-4. [pmid: 11034526].
760 Krieger JN, Jacobs RR, Ross SO. Does the chronic prostatitis/pelvic pain syndrome differ from nonbacterial prostatitis and prostatodynia?. J Urol. 2000;164(5):1554-8. X-2, X-3, X-4. [pmid: 11025703].
761 Strohmaier WL, Bichler KH. Comparison of symptoms, morphological, microbiological and urodynamic findings in patients with chronic prostatitis/pelvic pain syndrome. Is it possible to differentiate separate categories?. Urol Int. 2000;65(2):112-6. X-2, X-3, X-4. [pmid: 11025434].
762 Zermann D, et al. Perisphincteric injection of botulinum toxin type A. A treatment option for patients with chronic prostatic pain?. Eur Urol. 2000;38(4):393-9. X-2, X-3, X-4. [pmid: 11025376].
763 Margaria E, et al. Recurrent pelvic pain in women. Curr Rev Pain. 2000;4(2):134-6. X-2, X-3, X-4, X-5. [pmid: 10998725].
764 Krieger JN, et al. Bacterial dna sequences in prostate tissue from patients with prostate cancer and chronic prostatitis. J Urol. 2000;164(4):1221-8. X-2, X-3, X-4. [pmid: 10992370].
765 Haefner HK, et al. Use of the McGill Pain Questionnaire to compare women with vulvar pain, pelvic pain and headaches. J Reprod Med. 2000;45(8):665-71. X-2, X-3, X-4, X-5. [pmid: 10986687].
766 Reed BD, et al. Psychosocial and sexual functioning in women with vulvodynia and chronic pelvic pain. A comparative evaluation. J Reprod Med. 2000;45(8):624-32. X-2, X-3, X-4, X-5. [pmid: 10986680].
767 Shahed AR, Shoskes DA. Oxidative stress in prostatic fluid of patients with chronic pelvic pain syndrome: correlation with gram positive bacterial growth and treatment response. J Androl. 2000;21(5):669-75. X-2, X-3, X-4. [pmid: 10975414].
768 Shoskes DA, Shahed AR. Detection of bacterial signal by 16S rRNA polymerase chain reaction in expressed prostatic secretions predicts response to antibiotic therapy in men with chronic pelvic pain syndrome. Tech Urol. 2000;6(3):240-2. X-2, X-3, X-4. [pmid: 10963501].
769 Nickel JC, et al. Pentosan polysulfate therapy for chronic nonbacterial prostatitis (chronic pelvic pain syndrome category IIIA): a prospective multicenter clinical trial. Urology. 2000;56(3):413-7. X-2, X-3, X-4. [pmid: 10962305].
770 Rapkin A, et al. Peritoneal fluid interleukin-6 in women with chronic pelvic pain. Fertil Steril. 2000;74(2):325-8. X-3, X-4, X-5. [pmid: 10927052].
771 Harris RD, Holtzman SR, Poppe AM. Clinical outcome in female patients with pelvic pain and normal pelvic US findings. Radiology. 2000;216(2):440-3. X-2, X-3, X-4, X-5. [pmid: 10924567].
772 Hurst BS, et al. Delayed oral estradiol combined with leuprolide increases endometriosis-related pain. JSLS. 2000;4(2):97-101. X-3. [pmid: 10917114].
773 Etuk SJ, Asuquo EE, Itam IH. Laparoscopy in the management of pelvic pain in Calabar, Nigeria. Trop Doct. 2000;30(3):140-3. X-2, X-3, X-4, X-5. [pmid: 10902469].
774 Wreje U, et al. Collagen metabolism markers as a reflection of bone and soft tissue turnover during the menstrual cycle and oral contraceptive use. Contraception. 2000;61(4):265-70. X-3, X-4. [pmid: 10899482].
775 Ponniah S, Arah I, Alexander RB. PSA is a candidate self-antigen in autoimmune chronic prostatitis/chronic pelvic pain syndrome. Prostate. 2000;44(1):49-54. X-2, X-3, X-4. [pmid: 10861757].
776 Nadler RB, et al. IL-1beta and TNF-alpha in prostatic secretions are indicators in the evaluation of men with chronic prostatitis. J Urol. 2000;164(1):214-8. X-2. [pmid: 10840462].
777 Stevermer JJ, Easley SK. Treatment of prostatitis. Am Fam Physician. 2000;61(10):3015-22. 3025. 6. X-1, X-2, X-3, X-4. [pmid: 10839552].
778 Henry-Suchet J. PID: clinical and laparoscopic aspects. Ann N Y Acad Sci. 2000;900:301-8. X-1, X-2, X-3, X-4, X-5. [pmid: 10818418].
779 Coker AL, et al. Physical health consequences of physical and psychological intimate partner violence. Arch Fam Med. 2000;9(5):451-7. X-2, X-3, X-4, X-5. [pmid: 10810951].
780 Gargiulo T, Leo L, Gomel V. Laparoscopic uterine suspension using three-stitch technique. J Am Assoc Gynecol Laparosc. 2000;7(2):233-6. X-3. [pmid: 10806268].
781 Demco LA. Pain referral patterns in the pelvis. J Am Assoc Gynecol Laparosc. 2000;7(2):181-3. X-3, X-4, X-5. [pmid: 10806259].
782 Cho IR, et al. Prostate blood flow characteristics in the chronic prostatitis/pelvic pain syndrome. J Urol. 2000;163(4):1130-3. X-2, X-3, X-4. [pmid: 10737481].
783 Rein DB, et al. Direct medical cost of pelvic inflammatory disease and its sequelae: decreasing, but still substantial. Obstet Gynecol. 2000;95(3):397-402. X-2, X-3, X-4. [pmid: 10711551].
784 Trolice MP, Fishburne C Jr, McGrady S. Anesthetic efficacy of intrauterine lidocaine for endometrial biopsy: a randomized double-masked trial. Obstet Gynecol. 2000;95(3):345-7. X-3, X-4. [pmid: 10711541].
785 Mohiuddin M, et al. Preoperative chemoradiation in fixed distal rectal cancer: dose time factors for pathological complete response. Int J Radiat Oncol Biol Phys. 2000;46(4):883-8. X-3, X-4. [pmid: 10705009].
786 Foong LC, et al. Altered peripheral vascular response of women with and without pelvic pain due to congestion. BJOG. 2000;107(2):157-64. X-3, X-4. [pmid: 10688497].
787 Krieger JN, Jacobs R, Ross SO. Detecting urethral and prostatic inflammation in patients with chronic prostatitis. Urology. 2000;55(2):186-91. discussion 191-2. X-2, X-3, X-4. [pmid: 10688076].
788 Ludwig M, et al. Comparison of expressed prostatic secretions with urine after prostatic massage--a means to diagnose chronic prostatitis/inflammatory chronic pelvic pain syndrome. Urology. 2000;55(2):175-7. X-2, X-3, X-4. [pmid: 10688073].
789 Papathanasiou K, et al. Our experience in laparoscopic diagnosis and management in women with chronic pelvic pain. Clin Exp Obstet Gynecol. 1999;26(3-4):190-2. X-3, X-4. [pmid: 10668153].
790 Emmanuel AV, Kamm MA, Beard RW. Reproducible assessment of vaginal and rectal mucosal and skin blood flow: laser doppler fluximetry of the pelvic microcirculation. Clin Sci (Lond). 2000;98(2):201-7. X-2, X-3, X-4. [pmid: 10657276].
791 Albert H. Psychosomatic group treatment helps women with chronic pelvic pain. J Psychosom Obstet Gynaecol. 1999;20(4):216-25. X-3. [pmid: 10656156].
792 Malik E, et al. Subjective evaluation of the therapeutic value of laparoscopic adhesiolysis: a retrospective analysis. Surg Endosc. 2000;14(1):79-81. X-3. [pmid: 10653243].
793 Martin S. Helping patients with chronic pelvic pain. Nursing. 1999;29(11):66. X-1, X-2, X-3, X-4, X-5. [pmid: 10633727].
794 Hochreiter WW, et al. Evaluation of the cytokines interleukin 8 and epithelial neutrophil activating peptide 78 as indicators of inflammation in prostatic secretions. Urology. 2000;56(6):1025-9. X-2, X-3, X-4. [pmid: 11113752].
795 Clemens JQ, et al. Biofeedback, pelvic floor re-education, and bladder training for male chronic pelvic pain syndrome. Urology. 2000;56(6):951-5. X-2, X-3, X-4. [pmid: 11113739].
796 Shoskes DA, et al. Quercetin in men with category III chronic prostatitis: a preliminary prospective, double-blind, placebo-controlled trial. Urology. 1999;54(6):960-3. X-2, X-3, X-4. [pmid: 10604689].
797 Hochreiter WW, Duncan JL, Schaeffer AJ. Evaluation of the bacterial flora of the prostate using a 16S rRNA gene based polymerase chain reaction. J Urol. 2000;163(1):127-30. X-2, X-3, X-4. [pmid: 10604329].
798 Baker FC, et al. High nocturnal body temperatures and disturbed sleep in women with primary dysmenorrhea. Am J Physiol. 1999;277(6 Pt 1):E1013-21. X-2, X-3, X-4. [pmid: 10600789].
799 Gogusev J, et al. Detection of DNA copy number changes in human endometriosis by comparative genomic hybridization. Hum Genet. 1999;105(5):444-51. X-3, X-4. [pmid: 10598811].
800 True LD, et al. Prostate histopathology and the chronic prostatitis/chronic pelvic pain syndrome: a prospective biopsy study. J Urol. 1999;162(6):2014-8. X-2, X-3, X-4. [pmid: 10569559].
801 Zondervan KT, et al. Patterns of diagnosis and referral in women consulting for chronic pelvic pain in UK primary care. Br J Obstet Gynaecol. 1999;106(11):1156-61. X-4. [pmid: 10549960].
802 Zondervan KT, et al. Prevalence and incidence of chronic pelvic pain in primary care: evidence from a national general practice database. Br J Obstet Gynaecol. 1999;106(11):1149-55. X-2, X-3, X-4. [pmid: 10549959].
803 Porpora MG, et al. Correlation between endometriosis and pelvic pain. J Am Assoc Gynecol Laparosc. 1999;6(4):429-34. X-3. [pmid: 10548700].
804 Kephart W. Evaluation of Lovelace Health Systems chronic pelvic pain protocol. Am J Manag Care. 1999;5(5 Suppl):S309-15. X-1, X-2, X-3, X-4, X-5. [pmid: 10537663].
805 Winkel CA. Modeling of medical and surgical treatment costs of chronic pelvic pain: new paradigms for making clinical decisions. Am J Manag Care. 1999;5(5 Suppl):S276-90. X-2, X-3, X-4. [pmid: 10537662].
806 Corsi PJ, et al. Transvaginal ultrasound-guided aspiration of pelvic abscesses. Infect Dis Obstet Gynecol. 1999;7(5):216-21. X-2, X-3, X-4. [pmid: 10524665].
807 Vercellini P, et al. A levonorgestrel-releasing intrauterine system for the treatment of dysmenorrhea associated with endometriosis: a pilot study. Fertil Steril. 1999;72(3):505-8. X-2, X-3, X-4. [pmid: 10519624].
808 Nag S, Martinez-Monge R, Martin EW. Intraoperative electron beam radiotherapy in recurrent colorectal carcinoma. J Surg Oncol. 1999;72(2):66-71. X-3, X-4. [pmid: 10518101].
809 Bodden-Heidrich R, et al. Chronic pelvic pain syndrome (CPPS) and chronic vulvar pain syndrome (CVPS): evaluation of psychosomatic aspects. J Psychosom Obstet Gynaecol. 1999;20(3):145-51. X-3, X-4, X-5. [pmid: 10497757].
810 Morgante G, et al. Low-dose danazol after combined surgical and medical therapy reduces the incidence of pelvic pain in women with moderate and severe endometriosis. Hum Reprod. 1999;14(9):2371-4. X-3. [pmid: 10469713].
811 Gurel H, Atar Gurel S. Dyspareunia, back pain and chronic pelvic pain: the importance of this pain complex in gynecological practice and its relation with grandmultiparity and pelvic relaxation. Gynecol Obstet Invest. 1999;48(2):119-22. X-4, X-5. [pmid: 10461003].
812 Hassan E, et al. Evaluation of combined endoscopic and pharmaceutical management of endometriosis during adolescence. Clin Exp Obstet Gynecol. 1999;26(2):85-7. X-3. [pmid: 10459444].
813 Kontoravdis A, et al. Laparoscopic evaluation and management of chronic pelvic pain during adolescence. Clin Exp Obstet Gynecol. 1999;26(2):76-7. X-3, X-4, X-5. [pmid: 10459441].
814 El-Minawi AM, Howard FM. Operative laparoscopic treatment of ovarian retention syndrome. J Am Assoc Gynecol Laparosc. 1999;6(3):297-302. X-3. [pmid: 10459030].
815 Clayton RD, et al. Recurrent pain after hysterectomy and bilateral salpingo-oophorectomy for endometriosis: evaluation of laparoscopic excision of residual endometriosis. Br J Obstet Gynaecol. 1999;106(7):740-4. X-3. [pmid: 10428534].
816 Parazzini F, et al. Oral contraceptive use and risk of endometriosis. Italian Endometriosis Study Group. Br J Obstet Gynaecol. 1999;106(7):695-9. X-3, X-4, X-5. [pmid: 10428526].
817 Vercellini P, et al. A gonadotrophin-releasing hormone agonist compared with expectant management after conservative surgery for symptomatic endometriosis. Br J Obstet Gynaecol. 1999;106(7):672-7. X-2. [pmid: 10428523].
818 Litwin MS, et al. The National Institutes of Health chronic prostatitis symptom index: development and validation of a new outcome measure. Chronic Prostatitis Collaborative Research Network. J Urol. 1999;162(2):369-75. X-2, X-3, X-4. [pmid: 10411041].
819 Schaeffer AJ. Prostatitis: US perspective. Int J Antimicrob Agents. 1999;11(3-4):205-11. discussion 213-6. X-1, X-2, X-3, X-4. [pmid: 10394972].
820 Ostrzenski A. A new laparoscopic retroperitoneal posterior culdoplasty technique. J Reprod Med. 1999;44(6):504-10. X-3, X-4, X-5. [pmid: 10394544].
821 Pavletic AJ, et al. Infertility following pelvic inflammatory disease. Infect Dis Obstet Gynecol. 1999;7(3):145-52. X-2, X-3, X-4. [pmid: 10371473].
822 Carter JE. Carter-Thomason uterine suspension and positioning by ligament investment, fixation and truncation. J Reprod Med. 1999;44(5):417-22. X-2, X-3, X-4, X-5. [pmid: 10360253].
823 Bianchi S, et al. Effects of 3 month therapy with danazol after laparoscopic surgery for stage III/IV endometriosis: a randomized study. Hum Reprod. 1999;14(5):1335-7. X-2. [pmid: 10325289].
824 Dolan JG, Howard FM. A survey of gynecologists' attitudes regarding decision making in the management of non-cancerous conditions that frequently result in hysterectomy. Med Decis Making. 1999;19(2):186-92. X-2, X-3. [pmid: 10231081].
825 Jaenisch JB, Junior WA. 100 total laparoscopic hysterectomies in private practice in Brazil. J Am Assoc Gynecol Laparosc. 1999;6(2):169-71. X-2, X-3, X-4, X-5. [pmid: 10226127].
826 Heim C, et al. Psychological and endocrine correlates of chronic pelvic pain associated with adhesions. J Psychosom Obstet Gynaecol. 1999;20(1):11-20. X-3. [pmid: 10212883].
827 Dwyer PL, Carey MP, Rosamilia A. Suture injury to the urinary tract in urethral suspension procedures for stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):15-21. X-2, X-3, X-4, X-5. [pmid: 10207762].
828 Treloar SA, et al. Predictors of hysterectomy: an Australian study. Am J Obstet Gynecol. 1999;180(4):945-54. X-4. [pmid: 10203663].
829 Leskinen M, Lukkarinen O, Marttila T. Effects of finasteride in patients with inflammatory chronic pelvic pain syndrome: a double-blind, placebo-controlled, pilot study. Urology. 1999;53(3):502-5. X-2, X-3, X-4. [pmid: 10096374].
830 Morales AJ, Murphy AA. Endoscopic treatment for endometriosis. Obstet Gynecol Clin North Am. 1999;26(1):121-33. X-1, X-2, X-3, X-5. [pmid: 10083934].
831 Palter SF. Office microlaparoscopy under local anesthesia. Obstet Gynecol Clin North Am. 1999;26(1):109-20. vii. X-1, X-2, X-3, X-4, X-5. [pmid: 10083933].
832 Morikawa JH. Laparoscopy for chronic pelvic pain. Hawaii Med J. 1999;58(1):22-3. X-1, X-2, X-3, X-4, X-5. [pmid: 10052271].
833 Ehlert U, Heim C, Hellhammer DH. Chronic pelvic pain as a somatoform disorder. Psychother Psychosom. 1999;68(2):87-94. X-3. [pmid: 10026460].
834 Perry CP. Relationship of gynecologic surgery to constipation. J Am Assoc Gynecol Laparosc. 1999;6(1):75-8. X-3, X-4, X-5. [pmid: 9971856].
835 Busacca M, et al. Follow-up of laparoscopic treatment of stage III-IV endometriosis. J Am Assoc Gynecol Laparosc. 1999;6(1):55-8. X-2, X-3. [pmid: 9971852].
836 Horgan M, Bersoff-Matcha S. Sexually transmitted diseases and HIV. A female perspective. Dermatol Clin. 1998;16(4):847-51. xv. xvi. X-1, X-2, X-3, X-4, X-5. [pmid: 9891693].
837 Demco LA. Effect on negative laparoscopy rate in chronic pelvic pain patients using patient assisted laparoscopy. JSLS. 1997;1(4):319-21. X-3. [pmid: 9876695].
838 Beretta P, et al. Randomized clinical trial of two laparoscopic treatments of endometriomas: cystectomy versus drainage and coagulation. Fertil Steril. 1998;70(6):1176-80. X-2, X-3, X-4. [pmid: 9848316].
839 Leon EL, et al. Laparoscopic management of small bowel obstruction: indications and outcome. J Gastrointest Surg. 1998;2(2):132-40. X-2, X-3, X-4. [pmid: 9834408].
840 Selfe SA, Matthews Z, Stones RW. Factors influencing outcome in consultations for chronic pelvic pain. J Womens Health. 1998;7(8):1041-8. X-2, X-4. [pmid: 9812301].
841 Cordts PR, et al. Pelvic congestion syndrome: early clinical results after transcatheter ovarian vein embolization. J Vasc Surg. 1998;28(5):862-8. X-3. [pmid: 9808854].
842 Hahn PM, Wong J, Reid RL. Menopausal-like hot flashes reported in women of reproductive age. Fertil Steril. 1998;70(5):913-8. X-2, X-3, X-4, X-5. [pmid: 9806575].
843 Alexander RB, et al. Elevated levels of proinflammatory cytokines in the semen of patients with chronic prostatitis/chronic pelvic pain syndrome. Urology. 1998;52(5):744-9. X-2, X-3, X-4. [pmid: 9801092].
844 Almeida OD Jr, Val-Gallas JM. Office microlaparoscopy under local anesthesia in the diagnosis and treatment of chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1998;5(4):407-10. X-3, X-4. [pmid: 9782146].
845 Waxman JA, Sulak PJ, Kuehl TJ. Cystoscopic findings consistent with interstitial cystitis in normal women undergoing tubal ligation. J Urol. 1998;160(5):1663-7. X-2, X-3, X-4. [pmid: 9783927].
846 Duleba AJ, et al. Changes in personality profile associated with laparoscopic surgery for chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1998;5(4):389-95. X-3. [pmid: 9782144].
847 Selfe SA, Van Vugt M, Stones RW. Chronic gynaecological pain: an exploration of medical attitudes. Pain. 1998;77(2):215-25. X-2, X-3, X-4. [pmid: 9766840].
848 Novicki DE, Larson TR, Swanson SK. Interstitial cystitis in men. Urology. 1998;52(4):621-4. X-2, X-3, X-4. [pmid: 9763081].
849 Barbieri RL. Stenosis of the external cervical os: an association with endometriosis in women with chronic pelvic pain. Fertil Steril. 1998;70(3):571-3. X-3, X-4. [pmid: 9757894].
850 Busacca M, et al. Surgical treatment of recurrent endometriosis: laparotomy versus laparoscopy. Hum Reprod. 1998;13(8):2271-4. X-3. [pmid: 9756309].
851 Urbach DR, et al. Bowel resection for intestinal endometriosis. Dis Colon Rectum. 1998;41(9):1158-64. X-3. [pmid: 9749501].
852 Ness RB, et al. Design of the PID Evaluation and Clinical Health (PEACH) Study. Control Clin Trials. 1998;19(5):499-514. X-2, X-3, X-4, X-5. [pmid: 9741869].
853 Fleischer AC, et al. Sonographic features of ovarian remnants. J Ultrasound Med. 1998;17(9):551-5. X-3. [pmid: 9733172].
854 Richter HE, et al. Laparoscopic and psychologic evaluation of women with chronic pelvic pain. Int J Psychiatry Med. 1998;28(2):243-53. X-3. [pmid: 9724892].
855 Yamada T, et al. The correction of type 2 stress incontinence with a polytetrafluoroethylene patch sling: 5-year mean followup. J Urol. 1998;160(3 Pt 1):746-9. X-2, X-3, X-4. [pmid: 9720537].
856 Schaeffer AJ. Prostatitis: US perspective. Int J Antimicrob Agents. 1998;10(2):153-9. X-1, X-2, X-3, X-4. [pmid: 9716292].
857 Bultitude M, Young J, Allan J. Loin pain haematuria syndrome: distress resolved by pain relief. Pain. 1998;76(1-2):209-13. X-3. [pmid: 9696475].
858 Chen FP, et al. The use of serum CA-125 as a marker for endometriosis in patients with dysmenorrhea for monitoring therapy and for recurrence of endometriosis. Acta Obstet Gynecol Scand. 1998;77(6):665-70. X-2, X-3, X-4, X-5. [pmid: 9688246].
859 Robert R, et al. Anatomic basis of chronic perineal pain: role of the pudendal nerve. Surg Radiol Anat. 1998;20(2):93-8. X-1, X-2, X-3, X-4. [pmid: 9658526].
860 Berkowitz CD. Medical consequences of child sexual abuse. Child Abuse Negl. 1998;22(6):541-50. discussion 551-4. X-1, X-2, X-3, X-4, X-5. [pmid: 9649894].
861 Heim C, et al. Abuse-related posttraumatic stress disorder and alterations of the hypothalamic-pituitary-adrenal axis in women with chronic pelvic pain. Psychosom Med. 1998;60(3):309-18. X-3, X-4. [pmid: 9625218].
862 Riley DE, et al. Diverse and related 16S rRNA-encoding DNA sequences in prostate tissues of men with chronic prostatitis. J Clin Microbiol. 1998;36(6):1646-52. X-2, X-3, X-4. [pmid: 9620394].
863 Heinrichs WL, Henzl MR. Human issues and medical economics of endometriosis. Three- vs. six-month GnRH-agonist therapy. J Reprod Med. 1998;43(3 Suppl):299-308. X-1, X-3. [pmid: 9564665].
864 Miklos JR, O'Reilly MJ, Saye WB. Sciatic hernia as a cause of chronic pelvic pain in women. Obstet Gynecol. 1998;91(6):998-1001. X-3. [pmid: 9611012].
865 Hickman TN, et al. Timing of estrogen replacement therapy following hysterectomy with oophorectomy for endometriosis. Obstet Gynecol. 1998;91(5 Pt 1):673-7. X-2, X-3. [pmid: 9572209].
866 Shaker HS, Hassouna M. Sacral root neuromodulation in idiopathic nonobstructive chronic urinary retention. J Urol. 1998;159(5):1476-8. X-2, X-3, X-4. [pmid: 9554336].
867 Bergqvist A, et al. Effects of triptorelin versus placebo on the symptoms of endometriosis. Fertil Steril. 1998;69(4):702-8. X-3. [pmid: 9548161].
868 ACOG criteria set. Hysterectomy, abdominal or vaginal for chronic pelvic pain. Number 29, November 1997. Committee on Quality Assessment. American College of Obstetricians and Gynecologists. Int J Gynaecol Obstet. 1998;60(3):316-7. X-1, X-2, X-3, X-4, X-5. [pmid: 9544724].
869 Emmert C, Romann D, Riedel HH. Endometriosis diagnosed by laparoscopy in adolescent girls. Arch Gynecol Obstet. 1998;261(2):89-93. X-2, X-3, X-4, X-5. [pmid: 9544374].
870 Engel CC Jr, et al. A randomized, double-blind crossover trial of sertraline in women with chronic pelvic pain. J Psychosom Res. 1998;44(2):203-7. X-3. [pmid: 9532549].
871 Muneyyirci-Delale O, Karacan M. Effect of norethindrone acetate in the treatment of symptomatic endometriosis. Int J Fertil Womens Med. 1998;43(1):24-7. X-3. [pmid: 9532466].
872 Tay SK, Bromwich N. Outcome of hysterectomy for pelvic pain in premenopausal women. Aust N Z J Obstet Gynaecol. 1998;38(1):72-6. X-3. [pmid: 9521396].
873 Venturini PL, et al. Chronic pelvic pain: oral contraceptives and non-steroidal anti-inflammatory compounds. Cephalalgia. Suppl 20. 1997;17:29-31. X-1, X-2, X-3. [pmid: 9496775].
874 Lebel G, et al. Organochlorine exposure and the risk of endometriosis. Fertil Steril. 1998;69(2):221-8. X-3, X-4, X-5. [pmid: 9496332].
875 Collett BJ, et al. A comparative study of women with chronic pelvic pain, chronic nonpelvic pain and those with no history of pain attending general practitioners. Br J Obstet Gynaecol. 1998;105(1):87-92. X-3, X-4. [pmid: 9442168].
876 Karabacak O, et al. Small diameter versus conventional laparoscopy: a prospective, self-controlled study. Hum Reprod. 1997;12(11):2399-401. X-3. [pmid: 9436672].
877 Alexander RB, Brady F, Ponniah S. Autoimmune prostatitis: evidence of T cell reactivity with normal prostatic proteins. Urology. 1997;50(6):893-9. X-2, X-3, X-4. [pmid: 9426720].
878 Plancarte R, et al. Neurolytic superior hypogastric plexus block for chronic pelvic pain associated with cancer. Reg Anesth. 1997;22(6):562-8. X-2, X-3, X-4, X-5. [pmid: 9425974].
879 Chen FP, Soong YK. The efficacy and complications of laparoscopic presacral neurectomy in pelvic pain. Obstet Gynecol. 1997;90(6):974-7. X-3. [pmid: 9397114].
880 Tarazov PG, Prozorovskij KV, Ryzhkov VK. Pelvic pain syndrome caused by ovarian varices. Treatment by transcatheter embolization. Acta Radiol. 1997;38(6):1023-5. X-3. [pmid: 9394662].
881 Laufer MR, et al. Prevalence of endometriosis in adolescent girls with chronic pelvic pain not responding to conventional therapy. J Pediatr Adolesc Gynecol. 1997;10(4):199-202. X-3. [pmid: 9391902].
882 deHoop TA, Mira J, Thomas MA. Endosalpingiosis and chronic pelvic pain. J Reprod Med. 1997;42(10):613-6. X-3. [pmid: 9350013].
883 Almeida OD Jr, Val-Gallas JM, Browning JL. A protocol for conscious sedation in microlaparoscopy. J Am Assoc Gynecol Laparosc. 1997;4(5):591-4. X-3, X-4, X-5. [pmid: 9348367].
884 Almeida OD Jr, Val-Gallas JM. Conscious pain mapping. J Am Assoc Gynecol Laparosc. 1997;4(5):587-90. X-3, X-4, X-5. [pmid: 9348366].
885 Laufer MR. Identification of clear vesicular lesions of atypical endometriosis: a new technique. Fertil Steril. 1997;68(4):739-40. X-3, X-4, X-5. [pmid: 9341623].
886 Elcombe S, Gath D, Day A. The psychological effects of laparoscopy on women with chronic pelvic pain. Psychol Med. 1997;27(5):1041-50. X-3. [pmid: 9300510].
887 Badura AS, et al. Dissociation, somatization, substance abuse, and coping in women with chronic pelvic pain. Obstet Gynecol. 1997;90(3):405-10. X-3, X-4. [pmid: 9277653].
888 Vercellini P, et al. Menstrual characteristics in women with and without endometriosis. Obstet Gynecol. 1997;90(2):264-8. X-4. [pmid: 9241306].
889 Goodwin SC, et al. Preliminary experience with uterine artery embolization for uterine fibroids. J Vasc Interv Radiol. 1997;8(4):517-26. X-3. [pmid: 9232565].
890 Stovall DW, et al. Endometriosis-associated pelvic pain: evidence for an association between the stage of disease and a history of chronic pelvic pain. Fertil Steril. 1997;68(1):13-8. X-3, X-4. [pmid: 9207577].
891 Heim C, et al. Psychoendocrinological observations in women with chronic pelvic pain. Ann N Y Acad Sci. 1997;821:456-8. X-3, X-4, X-5. [pmid: 9238228].
892 Regidor PA, et al. Long-term follow-up on the treatment of endometriosis with the GnRH-agonist buserelinacetate. Long-term follow-up data (up to 98 months) of 42 patients with endometriosis who were treated with GnRH-agonist buserelinacetate (Suprecur), were evaluated in respect of recurrence of pain symptoms and pregnancy outcome. Eur J Obstet Gynecol Reprod Biol. 1997;73(2):153-60. X-3. [pmid: 9228497].
893 Drabick JJ, Gambel JM, Mackey JF. Prostatodynia in United Nations peacekeeping forces in Haiti. Mil Med. 1997;162(6):380-3. X-2, X-3, X-4. [pmid: 9183157].
894 Hornstein MD, et al. Retreatment with nafarelin for recurrent endometriosis symptoms: efficacy, safety, and bone mineral density. Fertil Steril. 1997;67(6):1013-8. X-3. [pmid: 9176437].
895 von Theobald P, Barjot P, Levy G. Laparoscopic douglasectomy in the treatment of painful uterine retroversion. Surg Endosc. 1997;11(6):639-42. X-3. [pmid: 9171123].
896 Gurel SA, Gurel H. The effect of grandmultiparity on chronic pelvic pain and sexual discomfort. Int J Gynaecol Obstet. 1997;57(2):133-8. X-2, X-3, X-4, X-5. [pmid: 9184949].
897 Faber BM, Coddington CC 3rd. Microlaparoscopy: a comparative study of diagnostic accuracy. Fertil Steril. 1997;67(5):952-4. X-3, X-4. [pmid: 9130907].
898 Sall M, et al. Pelvic pain following radical retropubic prostatectomy: a prospective study. Urology. 1997;49(4):575-9. X-2, X-3, X-4. [pmid: 9111628].
899 Capasso P, et al. Treatment of symptomatic pelvic varices by ovarian vein embolization. Cardiovasc Intervent Radiol. 1997;20(2):107-11. X-3. [pmid: 9030500].
900 Surrey E. An economically rational method of managing early-stage endometriosis. Med Interface. 1997;10(3):119-24. X-1, X-2, X-3, X-4, X-5. [pmid: 10172946].
901 Hawk C, Long C, Azad A. Chiropractic care for women with chronic pelvic pain: a prospective single-group intervention study. J Manipulative Physiol Ther. 1997;20(2):73-9. X-3. [pmid: 9046454].
902 Dmowski WP, et al. Changing trends in the diagnosis of endometriosis: a comparative study of women with pelvic endometriosis presenting with chronic pelvic pain or infertility. Fertil Steril. 1997;67(2):238-43. X-2, X-3, X-4, X-5. [pmid: 9022596].
903 Ostensen M, Schei B. Sociodemographic characteristics and gynecological disease in 40-42 year old women reporting musculoskeletal disease. Scand J Rheumatol. 1997;26(6):426-34. X-2, X-3, X-4, X-5. [pmid: 9433402].
904 Fry RP, et al. Sociopsychological factors in women with chronic pelvic pain with and without pelvic venous congestion. J Psychosom Res. 1997;42(1):71-85. X-4, X-5. [pmid: 9055215].
905 Finan MA, et al. Surgical resection of endometriosis after prior hysterectomy. J La State Med Soc. 1997;149(1):32-5. X-3. [pmid: 9033193].
906 Ten Have TR, Landis JR, Hartzel J. Population-averaged and cluster-specific models for clustered ordinal response data. Stat Med. 1996;15(23):2573-88. X-1, X-2, X-3, X-4. [pmid: 8961464].
907 McDonald JS, et al. Visualization of compression neuropathies through volume deformation. Stud Health Technol Inform. 1997;39:99-106. X-2, X-3, X-4, X-5. [pmid: 10168959].
908 Crosignani PG, et al. Leuprolide in a 3-monthly versus a monthly depot formulation for the treatment of symptomatic endometriosis: a pilot study. Hum Reprod. 1996;11(12):2732-5. X-3. [pmid: 9021380].
909 Falck HR. Psychoanalytic group therapy in the treatment of severe psychosomatic dysfunctions--experiences since 1981. J Psychosom Obstet Gynaecol. 1996;17(4):235-7. X-1, X-2, X-3, X-4, X-5. [pmid: 8997690].
910 Ostgaard HC, Roos-Hansson E, Zetherstrom G. Regression of back and posterior pelvic pain after pregnancy. Spine (Phila Pa 1976). 1996;21(23):2777-80. X-2, X-3, X-4. [pmid: 8979325].
911 Howard FM. The role of laparoscopy in the evaluation of chronic pelvic pain: pitfalls with a negative laparoscopy. J Am Assoc Gynecol Laparosc. 1996;4(1):85-94. X-1, X-2, X-3, X-4, X-5. [pmid: 9050719].
912 Phillips DR, et al. Laparoscopic bipolar coagulation for the conservative treatment of adenomyomata. J Am Assoc Gynecol Laparosc. 1996;4(1):19-24. X-3. [pmid: 9050706].
913 Orford VP, Kuhn RJ. Management of ovarian remnant syndrome. Aust N Z J Obstet Gynaecol. 1996;36(4):468-71. X-1, X-2, X-3. [pmid: 9006836].
914 Crosignani PG, et al. Laparoscopy versus laparotomy in conservative surgical treatment for severe endometriosis. Fertil Steril. 1996;66(5):706-11. X-2, X-3. [pmid: 8893671].
915 ACOG releases a report on chronic pelvic pain. American College of Obstetricians and Gynecologists. Am Fam Physician. 1996;54(5):1793-4. X-1, X-2, X-3, X-4, X-5. [pmid: 8857797].
916 Newham AP, van der Spuy ZM, Nugent F. Laparoscopic findings in women with chronic pelvic pain. S Afr Med J. 1996;86(9 Suppl):1200-3. X-2, X-3, X-4, X-5. [pmid: 9180785].
917 Dekel A, et al. The residual ovary syndrome: a 20-year experience. Eur J Obstet Gynecol Reprod Biol. 1996;68(1-2):159-64. X-3, X-5. [pmid: 8886700].
918 Levine DJ, Botney K. The classic intrafascial Semm hysterectomy as an alternative to abdominal hysterectomy. J Am Assoc Gynecol Laparosc. 1996;3(4):545-8. X-2, X-3, X-4, X-5. [pmid: 9050686].
919 Petros PP. Severe chronic pelvic pain in women may be caused by ligamentous laxity in the posterior fornix of the vagina. Aust N Z J Obstet Gynaecol. 1996;36(3):351-4. X-3, X-4. [pmid: 8883767].
920 Mens JM, et al. Understanding peripartum pelvic pain. Implications of a patient survey. Spine (Phila Pa 1976). 1996;21(11):1363-9. discussion 1369-70. X-2, X-3, X-4, X-5. [pmid: 8725930].
921 Palter SF, Olive DL. Office microlaparoscopy under local anesthesia for chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1996;3(3):359-64. X-2, X-3, X-4, X-5. [pmid: 9050656].
922 Zadinsky JK, Boyle JS. Experiences of women with chronic pelvic pain. Health Care Women Int. 1996;17(3):223-32. X-3, X-4. [pmid: 8852224].
923 Zanetta G, et al. Safety of transvaginal fine needle puncture of gynecologic masses: a report after 500 consecutive procedures. J Ultrasound Med. 1996;15(5):401-4. X-4. [pmid: 8731449].
924 Vercellini P, et al. Laparoscopic uterine biopsy for diagnosing diffuse adenomyosis. J Reprod Med. 1996;41(4):220-4. X-2, X-3, X-4. [pmid: 8728071].
925 Chapron C, Dubuisson JB. Laparoscopic treatment of deep endometriosis located on the uterosacral ligaments. Hum Reprod. 1996;11(4):868-73. X-3. [pmid: 8671342].
926 Hanna L, Highleyman L. Pelvic inflammatory disease. BETA. 1996:28-31. 44. X-1, X-2, X-3, X-4, X-5.
927 Peveler R, et al. Psychosocial factors and chronic pelvic pain: a comparison of women with endometriosis and with unexplained pain. J Psychosom Res. 1996;40(3):305-15. X-3, X-5. [pmid: 8861127].
928 Walker EA, et al. Chronic pelvic pain and gynecological symptoms in women with irritable bowel syndrome. J Psychosom Obstet Gynaecol. 1996;17(1):39-46. X-2, X-3. [pmid: 8860885].
929 Kontoravdis A, et al. The diagnostic value of laparoscopy in 2365 patients with acute and chronic pelvic pain. Int J Gynaecol Obstet. 1996;52(3):243-8. X-2, X-3, X-4, X-5. [pmid: 8775676].
930 Hansen A, et al. Relaxin is not related to symptom-giving pelvic girdle relaxation in pregnant women. Acta Obstet Gynecol Scand. 1996;75(3):245-9. X-2, X-3, X-4. [pmid: 8607337].
931 Glynn C, O'sullivan K. A double-blind randomised comparison of the effects of epidural clonidine, lignocaine and the combination of clonidine and lignocaine in patients with chronic pain. Pain. 1996;64(2):337-43. X-3. [pmid: 8740612].
932 Ruifang W, et al. Relationship between prostaglandin in peritoneal fluid and pelvic venous congestion after sterilization. Prostaglandins. 1996;51(2):161-7. X-3, X-4. [pmid: 8711137].
933 Balasch J, et al. Visible and non-visible endometriosis at laparoscopy in fertile and infertile women and in patients with chronic pelvic pain: a prospective study. Hum Reprod. 1996;11(2):387-91. X-3, X-4. [pmid: 8671229].
934 Vercellini P, et al. Endometriosis and pelvic pain: relation to disease stage and localization. Fertil Steril. 1996;65(2):299-304. X-2, X-3, X-4. [pmid: 8566252].
935 Karck U, et al. PGE2 and PGF2 alpha release by human peritoneal macrophages in endometriosis. Prostaglandins. 1996;51(1):49-60. X-3, X-4, X-5. [pmid: 8900443].
936 Fry RP, Stones RW. Hostility and doctor-patient interaction in chronic pelvic pain. Psychother Psychosom. 1996;65(5):253-7. X-3, X-4, X-5. [pmid: 8893326].
937 Gerber B, Krause A. A study of second-look laparoscopy after acute salpingitis. Arch Gynecol Obstet. 1996;258(4):193-200. X-3. [pmid: 8844136].
938 Ekberg O, Sjoberg S, Westlin N. Sports-related groin pain: evaluation with MR imaging. Eur Radiol. 1996;6(1):52-5. X-3, X-4. [pmid: 8797950].
939 Hur M, et al. Laparoscopically assisted vaginal hysterectomy. J Reprod Med. 1995;40(12):829-33. X-2, X-3, X-4, X-5. [pmid: 8926611].
940 Liang CC, Soong YK, Ho YS. Endometriosis in adolescent women. Changgeng Yi Xue Za Zhi. 1995;18(4):315-21. X-2, X-3. [pmid: 8851979].
941 Toomey TC, et al. Relationship of sexual and physical abuse to pain description, coping, psychological distress, and health-care utilization in a chronic pain sample. Clin J Pain. 1995;11(4):307-15. X-2, X-3, X-4, X-5. [pmid: 8788578].
942 Taner CE, et al. Menstrual disorders and pelvic pain after sterilization. Adv Contracept. 1995;11(4):309-15. X-3, X-4. [pmid: 8659316].
943 Hillis SD, Marchbanks PA, Peterson HB. The effectiveness of hysterectomy for chronic pelvic pain. Obstet Gynecol. 1995;86(6):941-5. X-3. [pmid: 7501344].
944 Keltz MD, et al. Large bowel-to-pelvic sidewall adhesions associated with chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1995;3(1):55-9. X-3, X-4, X-5. [pmid: 9050617].
945 Phillips DR, et al. 100 laparoscopic hysterectomies in private practice and visiting professorship programs. J Am Assoc Gynecol Laparosc. 1995;3(1):47-53. X-2, X-3, X-5. [pmid: 9050616].
946 Grace VM. Problems of communication, diagnosis, and treatment experienced by women using the New Zealand health services for chronic pelvic pain: a quantitative analysis. Health Care Women Int. 1995;16(6):521-35. X-3, X-4, X-5. [pmid: 8707687].
947 Grace VM. Problems women patients experience in the medical encounter for chronic pelvic pain: a New Zealand study. Health Care Women Int. 1995;16(6):509-19. X-3, X-4, X-5. [pmid: 8707686].
948 Walker EA, et al. Psychiatric diagnoses and sexual victimization in women with chronic pelvic pain. Psychosomatics. 1995;36(6):531-40. X-3. [pmid: 7501783].
949 Ravina JH, et al. Arterial embolisation to treat uterine myomata. Lancet. 1995;346(8976):671-2. X-2, X-3, X-4. [pmid: 7544859].
950 Sentovich SM, et al. Simultaneous dynamic proctography and peritoneography for pelvic floor disorders. Dis Colon Rectum. 1995;38(9):912-5. X-2, X-3, X-4. [pmid: 7656736].
951 Keltz MD, et al. Endosalpingiosis found at laparoscopy for chronic pelvic pain. Fertil Steril. 1995;64(3):482-5. X-3. [pmid: 7641898].
952 Wechsler RJ, et al. Superior hypogastric plexus block for chronic pelvic pain in the presence of endometriosis: CT techniques and results. Radiology. 1995;196(1):103-6. X-3. [pmid: 7784552].
953 Krolikowski A, Janowski K, Larsen JV. Laparoscopic and cystopic findings in patients with chronic pelvic pain in Eshowe, South Africa. Cent Afr J Med. 1995;41(7):225-6. X-3, X-4. [pmid: 7553796].
954 Ozaksit G, et al. Chronic pelvic pain in adolescent women. Diagnostic laparoscopy and ultrasonography. J Reprod Med. 1995;40(7):500-2. X-3, X-4. [pmid: 7473437].
955 Nezhat F, et al. Use of hysteroscopy in addition to laparoscopy for evaluating chronic pelvic pain. J Reprod Med. 1995;40(6):431-4. X-3, X-4, X-5. [pmid: 7650654].
956 Vilos GA, Alshimmiri MM. Cost-benefit analysis of laparoscopic versus laparotomy salpingo-oophorectomy for benign tubo-ovarian disease. J Am Assoc Gynecol Laparosc. 1995;2(3):299-303. X-2, X-3, X-4. [pmid: 9147861].
957 van Herendael B, et al. Management of adnexal masses by operative laparoscopy. J Am Assoc Gynecol Laparosc. 1995;2(3):273-7. X-2, X-3, X-4, X-5. [pmid: 9050570].
958 Carter JE. Laparoscopic treatment of chronic pelvic pain in 100 adult women. J Am Assoc Gynecol Laparosc. 1995;2(3):255-62. X-3. [pmid: 9050567].
959 Hornstein MD, et al. Prospective randomized double-blind trial of 3 versus 6 months of nafarelin therapy for endometriosis associated pelvic pain. Fertil Steril. 1995;63(5):955-62. X-2, X-3. [pmid: 7720940].
960 Marchini M, et al. Mitogen-induced lymphocyte proliferation and peripheral blood mononuclear cell beta-endorphin concentrations in primary dysmenorrhoea. Hum Reprod. 1995;10(4):815-7. X-2, X-3, X-4. [pmid: 7650127].
961 Fayez JA, Clark RR. Operative laparoscopy for the treatment of localized chronic pelvic-abdominal pain caused by postoperative adhesions. J Gynecol Surg. 1994;10(2):79-83. X-3. [pmid: 10172337].
962 AlSalilli M, Vilos GA. Prospective evaluation of laparoscopic appendectomy in women with chronic right lower quadrant pain. J Am Assoc Gynecol Laparosc. 1995;2(2):139-42. X-3. [pmid: 9050547].
963 Edwards LC, Pearce SA, Beard RW. Remediation of pain-related memory bias as a result of recovery from chronic pain. J Psychosom Res. 1995;39(2):175-81. X-3. [pmid: 7595875].
964 Varcaccio-Garofalo G, et al. Analgesic properties of electromagnetic field therapy in patients with chronic pelvic pain. Clin Exp Obstet Gynecol. 1995;22(4):350-4. X-3. [pmid: 8777794].
965 Kupesic S, et al. The value of transvaginal color Doppler in the assessment of pelvic inflammatory disease. Ultrasound Med Biol. 1995;21(6):733-8. X-3, X-4. [pmid: 8571460].
966 Vercellini P, et al. Very low dose danazol for relief of endometriosis-associated pelvic pain: a pilot study. Fertil Steril. 1994;62(6):1136-42. X-3. [pmid: 7525359].
967 Carter JE. Combined hysteroscopic and laparoscopic findings in patients with chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1994;2(1):43-7. X-3, X-4, X-5. [pmid: 9050532].
968 Parazzini F, et al. Postsurgical medical treatment of advanced endometriosis: results of a randomized clinical trial. Am J Obstet Gynecol. 1994;171(5):1205-7. X-2. [pmid: 7977520].
969 Hofmeister JF, et al. A noninvasive method for recording the electrical activity of the human uterus in vivo. Biomed Instrum Technol. 1994;28(5):391-404. X-2, X-3, X-4, X-5. [pmid: 7528078].
970 Howard FM. Laparoscopic evaluation and treatment of women with chronic pelvic pain. J Am Assoc Gynecol Laparosc. 1994;1(4 Pt 1):325-31. X-3. [pmid: 9138873].
971 Pittaway DE, Takacs P, Bauguess P. Laparoscopic adnexectomy: a comparison with laparotomy. Am J Obstet Gynecol. 1994;171(2):385-9. discussion 389-91. X-2, X-3, X-4, X-5. [pmid: 8059816].
972 Walling MK, et al. Abuse history and chronic pain in women: II. A multivariate analysis of abuse and psychological morbidity. Obstet Gynecol. 1994;84(2):200-6. X-3, X-5. [pmid: 8041530].
973 Walling MK, et al. Abuse history and chronic pain in women: I. Prevalences of sexual abuse and physical abuse. Obstet Gynecol. 1994;84(2):193-9. X-3, X-4, X-5. [pmid: 8041529].
974 Gillespie L. Destruction of the vesicoureteric plexus for the treatment of hypersensitive bladder disorders. Br J Urol. 1994;74(1):40-3. X-2, X-3, X-4, X-5. [pmid: 8044528].
975 Prevalence and anatomical distribution of endometriosis in women with selected gynaecological conditions: results from a multicentric Italian study. Gruppo italiano per lo studio dell'endometriosi. Hum Reprod. 1994;9(6):1158-62. X-2, X-3, X-4, X-5. [pmid: 7962393].
976 Williams FH, Maly BJ. Pain rehabilitation. 3. Cancer pain, pelvic pain, and age-related considerations. Arch Phys Med Rehabil. 1994;75(5 Spec No):S15-20. X-1, X-2, X-3, X-4. [pmid: 8185460].
977 Hillis SD. PID prevention: clinical and societal stakes. Hosp Pract (Off Ed). 1994;29(4):121-4. 129. 30. X-1, X-2, X-3, X-4, X-5. [pmid: 8144716].
978 Li TC, Cooke ID. The value of an absorbable adhesion barrier, Interceed, in the prevention of adhesion reformation following microsurgical adhesiolysis. Br J Obstet Gynaecol. 1994;101(4):335-9. X-3. [pmid: 8199081].
979 Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women's Health Study: I. Outcomes of hysterectomy. Obstet Gynecol. 1994;83(4):556-65. X-2, X-4. [pmid: 8134066].
980 Johnstone FD, et al. Immunohistochemical characterization of endometrial lymphoid cell populations in women infected with human immunodeficiency virus. Obstet Gynecol. 1994;83(4):586-93. X-3, X-4. [pmid: 7907778].
981 Perry CP, Perez J. The role for laparoscopic presacral neurectomy. J Gynecol Surg. 1993;9(3):165-8. X-3. [pmid: 10171990].
982 Redwine DB. Endometriosis persisting after castration: clinical characteristics and results of surgical management. Obstet Gynecol. 1994;83(3):405-13. X-2, X-3, X-4. [pmid: 8127534].
983 Low WY, Edelmann RJ, Sutton CJ. Patients with chronic pelvic pain and/or infertility: psychological differences pre- and post-treatment. J Psychosom Obstet Gynaecol. 1994;15(1):45-52. X-2, X-3, X-4. [pmid: 8038888].
984 Meterissian S, et al. Patterns of residual disease after preoperative chemoradiation in ultrasound T3 rectal carcinoma. Ann Surg Oncol. 1994;1(2):111-6. X-2, X-3, X-4. [pmid: 7834435].
985 Nezhat C, Santolaya J, Nezhat FR. Comparison of transvaginal sonography and bimanual pelvic examination in patients with laparoscopically confirmed endometriosis. J Am Assoc Gynecol Laparosc. 1994;1(2):127-30. X-3. [pmid: 9050474].
986 Steege JF. Repeated clinic laparoscopy for the treatment of pelvic adhesions: a pilot study. Obstet Gynecol. 1994;83(2):276-9. X-3. [pmid: 8290194].
987 Hamid R, et al. Laparoscopic appraisal of infertility and pelvic pain in Pakistani women: a 5 years audit. J Pak Med Assoc. 1994;44(2):40-2. X-2, X-3, X-4, X-5. [pmid: 8040992].
988 Hodgkiss AD, Sufraz R, Watson JP. Psychiatric morbidity and illness behaviour in women with chronic pelvic pain. J Psychosom Res. 1994;38(1):3-9. X-2, X-3. [pmid: 8126687].
989 Mais V, et al. The role of laparoscopy in the treatment of endometriosis. Clin Exp Obstet Gynecol. 1994;21(4):225-7. X-3. [pmid: 7994871].
990 Ajossa S, et al. The prevalence of endometriosis in premenopausal women undergoing gynecological surgery. Clin Exp Obstet Gynecol. 1994;21(3):195-7. X-2, X-3, X-4, X-5. [pmid: 7923803].
991 Jorgensen WA, Frome BM, Wallach C. Electrochemical therapy of pelvic pain: effects of pulsed electromagnetic fields (PEMF) on tissue trauma. Eur J Surg Suppl. 1994;(574):83-6. X-3. [pmid: 7531030].
992 Carter J, et al. Borderline and invasive epithelial ovarian tumors in young women. Obstet Gynecol. 1993;82(5):752-6. X-2, X-3, X-4. [pmid: 8414321].
993 Fukaya T, Hoshiai H, Yajima A. Is pelvic endometriosis always associated with chronic pain? A retrospective study of 618 cases diagnosed by laparoscopy. Am J Obstet Gynecol. 1993;169(3):719-22. X-3, X-4, X-5. [pmid: 8372886].
994 Saunders GH, Haggard MP. The influence of personality-related factors upon consultation for two different “marginal” organic pathologies with and without reports of auditory symptomatology. Ear Hear. 1993;14(4):242-8. X-3, X-4. [pmid: 8405728].
995 de Leon-Casasola OA, Kent E, Lema MJ. Neurolytic superior hypogastric plexus block for chronic pelvic pain associated with cancer. Pain. 1993;54(2):145-51. X-3. [pmid: 8233527].
996 Rulin MC, et al. Long-term effect of tubal sterilization on menstrual indices and pelvic pain. Obstet Gynecol. 1993;82(1):118-21. X-3, X-4, X-5. [pmid: 8515910].
997 Fry RP, et al. Psychosocial aspects of chronic pelvic pain, with special reference to sexual abuse. A study of 164 women. Postgrad Med J. 1993;69(813):566-74. X-3, X-4, X-5. [pmid: 8415346].
998 Foster DC, Robinson JC, Davis KM. Urethral pressure variation in women with vulvar vestibulitis syndrome. Am J Obstet Gynecol. 1993;169(1):107-12. X-3, X-4. [pmid: 8333432].
999 Drife JO. The pelvic pain syndrome. Br J Obstet Gynaecol. 1993;100(6):508-10. X-1, X-2, X-3, X-4, X-5. [pmid: 8334082].
1000 Heitkemper MM, et al. Women with gastrointestinal symptoms: implications for nursing research and practice. Gastroenterol Nurs. 1993;15(6):226-32. X-1, X-2, X-3, X-4, X-5. [pmid: 8323989].
1001 Witkin SS, et al. Detection of Chlamydia trachomatis by the polymerase chain reaction in the cervices of women with acute salpingitis. Am J Obstet Gynecol. 1993;168(5):1438-42. X-3. [pmid: 8498424].
1002 Turk PS, et al. Isolated pelvic perfusion for unresectable cancer using a balloon occlusion technique. Arch Surg. 1993;128(5):533-8. discussion 538-9. X-2, X-3, X-4. [pmid: 7683872].
1003 Gangar KF, et al. An alternative to hysterectomy? GnRH analogue combined with hormone replacement therapy. Br J Obstet Gynaecol. 1993;100(4):360-4. X-3. [pmid: 8494837].
1004 Heisterberg L. Factors influencing spontaneous abortion, dyspareunia, dysmenorrhea, and pelvic pain. Obstet Gynecol. 1993;81(4):594-7. X-3, X-4, X-5. [pmid: 8459974].
1005 Heloury Y, et al. Laparoscopy in adnexal pathology in the child: a study of 28 cases. Eur J Pediatr Surg. 1993;3(2):75-8. X-2, X-3, X-4. [pmid: 8323922].
1006 Toomey TC, et al. Relationship of sexual and physical abuse to pain and psychological assessment variables in chronic pelvic pain patients. Pain. 1993;53(1):105-9. X-3, X-4. [pmid: 8316381].
1007 Perez CA, et al. Irradiation in relapsing carcinoma of the prostate. Cancer. 1993;71(3 Suppl):1110-22. X-2, X-3, X-4. [pmid: 7679040].
1008 Dijkema HE, et al. Neuromodulation of sacral nerves for incontinence and voiding dysfunctions. Clinical results and complications. Eur Urol. 1993;24(1):72-6. X-2, X-3, X-4, X-5. [pmid: 8396034].
1009 Monk BJ, et al. Radical hysterectomy after pelvic irradiation in patients with high risk cervical cancer or uterine sarcoma: morbidity and outcome. Eur J Gynaecol Oncol. 1993;14(6):506-11. X-3, X-4. [pmid: 8181490].
1010 Nolan TE, Metheny WP, Smith RP. Unrecognized association of sleep disorders and depression with chronic pelvic pain. South Med J. 1992;85(12):1181-3. X-3. [pmid: 1470959].
1011 Waylonis GW, Heck W. Fibromyalgia syndrome. New associations. Am J Phys Med Rehabil. 1992;71(6):343-8. X-2, X-3, X-4, X-5. [pmid: 1466872].
1012 Sayegh R, Garcia CR. Ovarian function after conservational ovarian surgery: a long-term follow-up study. Int J Gynaecol Obstet. 1992;39(4):303-9. X-2, X-3, X-4, X-5. [pmid: 1361464].
1013 Walker EA, et al. Medical and psychiatric symptoms in women with childhood sexual abuse. Psychosom Med. 1992;54(6):658-64. X-3, X-4, X-5. [pmid: 1454959].
1014 Stones RW, Thomas DC, Beard RW. Suprasensitivity to calcitonin gene-related peptide but not vasoactive intestinal peptide in women with chronic pelvic pain. Clin Auton Res. 1992;2(5):343-8. X-3, X-4. [pmid: 1422102].
1015 Koss MP, Heslet L. Somatic consequences of violence against women. Arch Fam Med. 1992;1(1):53-9. X-1, X-2, X-3, X-4. [pmid: 1341588].
1016 Saleh MN, et al. Phase I trial of the murine monoclonal anti-GD2 antibody 14G2a in metastatic melanoma. Cancer Res. 1992;52(16):4342-7. X-2, X-3, X-4. [pmid: 1643631].
1017 Abiodun OA, Adetoro OO, Ogunbode OO. Psychiatric morbidity in a gynaecology clinic in Nigeria. J Psychosom Res. 1992;36(5):485-90. X-3, X-4, X-5. [pmid: 1619588].
1018 Vercellini P, et al. Laparoscopic aspiration of ovarian endometriomas. Effect with postoperative gonadotropin releasing hormone agonist treatment. J Reprod Med. 1992;37(7):577-80. X-3. [pmid: 1387905].
1019 Thomas DC, et al. Measurement of pelvic blood flow changes in response to posture in normal subjects and in women with pelvic pain owing to congestion by using a thermal technique. Clin Sci (Lond). 1992;83(1):55-8. X-3, X-4. [pmid: 1325322].
1020 Bonney RC, et al. Endometrial phospholipases A2, polycystic ovaries and pelvic pain. Br J Obstet Gynaecol. 1992;99(6):486-91. X-3, X-4. [pmid: 1637765].
1021 Vercellini P, Bocciolone L, Crosignani PG. Is mild endometriosis always a disease?. Hum Reprod. 1992;7(5):627-9. X-1, X-2, X-3, X-4. [pmid: 1639981].
1022 Levin KE, et al. Role of oxygen free radicals in the etiology of pouchitis. Dis Colon Rectum. 1992;35(5):452-6. X-2, X-3, X-4, X-5. [pmid: 1568395].
1023 Vercellini P, et al. Mononuclear cell beta-endorphin concentration in women with and without endometriosis. Obstet Gynecol. 1992;79(5 ( Pt 1)):743-6. X-3, X-4. [pmid: 1565359].
1024 Safrin S, et al. Long-term sequelae of acute pelvic inflammatory disease. A retrospective cohort study. Am J Obstet Gynecol. 1992;166(4):1300-5. X-2, X-3, X-4. [pmid: 1566789].
1025 Walker EA, et al. Dissociation in women with chronic pelvic pain. Am J Psychiatry. 1992;149(4):534-7. X-3, X-4. [pmid: 1554041].
1026 Baker PN, Symonds EM. The resolution of chronic pelvic pain after normal laparoscopy findings. Am J Obstet Gynecol. 1992;166(3):835-6. X-3, X-4, X-5. [pmid: 1532290].
1027 Bryson K. Laparoscopic appendectomy. J Gynecol Surg. 1991;7(2):93-5. X-2, X-3, X-4, X-5. [pmid: 10150024].
1028 Abu-Musa A, et al. CA-125 in menstrual discharge in patients with chronic pelvic pain. Int J Gynaecol Obstet. 1992;37(2):111-4. X-3, X-4, X-5. [pmid: 1348698].
1029 Nunez C, Diaz JI. Ovarian follicular cysts: a potential source of false positive diagnoses in ovarian cytology. Diagn Cytopathol. 1992;8(5):532-6. discussion 536-7. X-2, X-3, X-4, X-5. [pmid: 1396032].
1030 Aboulghar MA, et al. Ultrasonic transvaginal aspiration of endometriotic cysts: an optional line of treatment in selected cases of endometriosis. Hum Reprod. 1991;6(10):1408-10. X-3. [pmid: 1770136].
1031 Gillespie L, et al. Lumbar nerve root compression and interstitial cystitis--response to decompressive surgery. Br J Urol. 1991;68(4):361-4. X-3. [pmid: 1933154].
1032 Kasule J. Laparoscopic evaluation of chronic pelvic pain in Zimbabwean women. East Afr Med J. 1991;68(10):807-11. X-3, X-4, X-5. [pmid: 1839894].
1033 Beard RW, et al. Bilateral oophorectomy and hysterectomy in the treatment of intractable pelvic pain associated with pelvic congestion. Br J Obstet Gynaecol. 1991;98(10):988-92. X-3. [pmid: 1751445].
1034 Waldman SD, Wilson WL, Kreps RD. Superior hypogastric plexus block using a single needle and computed tomography guidance: description of a modified technique. Reg Anesth. 1991;16(5):286-7. X-1, X-2, X-3. [pmid: 1958609].
1035 Kettel LM, et al. Endocrine responses to long-term administration of the antiprogesterone RU486 in patients with pelvic endometriosis. Fertil Steril. 1991;56(3):402-7. X-3. [pmid: 1716596].
1036 Steege JF, Stout AL. Resolution of chronic pelvic pain after laparoscopic lysis of adhesions. Am J Obstet Gynecol. 1991;165(2):278-81. discussion 281-3. X-3. [pmid: 1831321].
1037 Wexner SD, et al. Neurophysiologic assessment of the anal sphincters. Dis Colon Rectum. 1991;34(7):606-12. X-3, X-4. [pmid: 2055146].
1038 Reiter RC, et al. Correlation between sexual abuse and somatization in women with somatic and nonsomatic chronic pelvic pain. Am J Obstet Gynecol. 1991;165(1):104-9. X-3, X-4, X-5. [pmid: 1853884].
1039 Marana R, et al. Evaluation of the correlation between endometriosis extent, age of the patients and associated symptomatology. Acta Eur Fertil. 1991;22(4):209-12. X-2, X-3, X-4, X-5. [pmid: 1844323].
1040 Vercellini P, et al. Peritoneal endometriosis. Morphologic appearance in women with chronic pelvic pain. J Reprod Med. 1991;36(7):533-6. X-2, X-3, X-4, X-5. [pmid: 1834841].
1041 Ostrzenski A. A new translaparoscopic approach in endometriosis treatment: a. CO2 laser endometriosis excision and/or vaporization. b. CO2 laser uterine nerve ablation. c. Uterine suspension with Falope Rings. d. Intraperitoneally 32% Dextran-70 installation. Mater Med Pol. 1991;23(3):168-71. X-3. [pmid: 1726845].
1042 Mahmood TA, et al. Menstrual symptoms in women with pelvic endometriosis. Br J Obstet Gynaecol. 1991;98(6):558-63. X-2, X-3, X-4, X-5. [pmid: 1873245].
1043 Tanum G, et al. Chemotherapy and radiation therapy for anal carcinoma. Survival and late morbidity. Cancer. 1991;67(10):2462-6. X-2, X-3, X-4. [pmid: 2015547].
1044 Reiter RC, Gambone JC. Nongynecologic somatic pathology in women with chronic pelvic pain and negative laparoscopy. J Reprod Med. 1991;36(4):253-9. X-3. [pmid: 1830102].
1045 Daniell JF, Kurtz BR, Gurley LD. Laser laparoscopic management of large endometriomas. Fertil Steril. 1991;55(4):692-5. X-3. [pmid: 1707014].
1046 Candiani GB, et al. Repetitive conservative surgery for recurrence of endometriosis. Obstet Gynecol. 1991;77(3):421-4. X-3. [pmid: 1992410].
1047 Silva PD, Kuffel ME, Beguin EA. Open laparoscopy simplifies instrumentation required for laparoscopic oophorectomy and salpingo-oophorectomy. Obstet Gynecol. 1991;77(3):482-5. X-3. [pmid: 1825137].
1048 al-Suleiman SA. Laparoscopy in the management of women with chronic pelvic pain. Aust N Z J Obstet Gynaecol. 1991;31(1):63-5. X-3, X-4, X-5. [pmid: 1831347].
1049 Walker EA, et al. An open trial of nortriptyline in women with chronic pelvic pain. Int J Psychiatry Med. 1991;21(3):245-52. X-3. [pmid: 1955276].
1050 Fry RP, Crisp AH, Beard RW. Patients' illness models in chronic pelvic pain. Psychother Psychosom. 1991;55(2-4):158-63. X-3, X-4, X-5. [pmid: 1891563].
1051 Ostgaard HC, Andersson GB, Wennergren M. The impact of low back and pelvic pain in pregnancy on the pregnancy outcome. Acta Obstet Gynecol Scand. 1991;70(1):21-4. X-2, X-3, X-4, X-5. [pmid: 1830444].
1052 Stout AL, et al. Relationship of laparoscopic findings to self-report of pelvic pain. Am J Obstet Gynecol. 1991;164(1 Pt 1):73-9. X-4. [pmid: 1824741].
1053 Drossman DA, et al. Sexual and physical abuse in women with functional or organic gastrointestinal disorders. Ann Intern Med. 1990;113(11):828-33. X-2, X-3, X-4, X-5. [pmid: 2240898].
1054 Farquhar CM, Hoghton GB, Beard RW. Pelvic pain--pelvic congestion or the irritable bowel syndrome?. Eur J Obstet Gynecol Reprod Biol. 1990;37(1):71-5. X-3. [pmid: 2376280].
1055 Yoong AF. Laparoscopic ventrosuspensions. A review of 72 cases. Am J Obstet Gynecol. 1990;163(4 Pt 1):1151-3. X-1, X-2, X-3. [pmid: 2145767].
1056 Longstreth GF, Preskill DB, Youkeles L. Irritable bowel syndrome in women having diagnostic laparoscopy or hysterectomy. Relation to gynecologic features and outcome. Dig Dis Sci. 1990;35(10):1285-90. X-2, X-3. [pmid: 2145139].
1057 Stones RW, et al. Pelvic congestion in women: evaluation with transvaginal ultrasound and observation of venous pharmacology. Br J Radiol. 1990;63(753):710-1. X-3. [pmid: 2205330].
1058 Gambone JC, et al. The impact of a quality assurance process on the frequency and confirmation rate of hysterectomy. Am J Obstet Gynecol. 1990;163(2):545-50. X-2, X-3, X-4, X-5. [pmid: 2386142].
1059 Plancarte R, et al. Superior hypogastric plexus block for pelvic cancer pain. Anesthesiology. 1990;73(2):236-9. X-3, X-5. [pmid: 2382849].
1060 Ramahi AJ, Richardson DA. A practical approach to the painful bladder syndrome. J Reprod Med. 1990;35(8):805-9. X-2, X-3, X-4. [pmid: 2213743].
1061 Rapkin AJ, et al. History of physical and sexual abuse in women with chronic pelvic pain. Obstet Gynecol. 1990;76(1):92-6. X-3, X-4. [pmid: 2359571].
1062 Adams J, et al. Uterine size and endometrial thickness and the significance of cystic ovaries in women with pelvic pain due to congestion. Br J Obstet Gynaecol. 1990;97(7):583-7. X-3, X-4, X-5. [pmid: 2202432].
1063 Tjaden B, et al. The efficacy of presacral neurectomy for the relief of midline dysmenorrhea. Obstet Gynecol. 1990;76(1):89-91. X-2, X-3, X-4. [pmid: 2193272].
1064 Vercellini P, et al. Laparoscopy in the diagnosis of gynecologic chronic pelvic pain. Int J Gynaecol Obstet. 1990;32(3):261-5. X-4. [pmid: 1972119].
1065 Perez JJ. Laparoscopic presacral neurectomy. Results of the first 25 cases. J Reprod Med. 1990;35(6):625-30. X-3. [pmid: 2141645].
1066 Kames LD, et al. Effectiveness of an interdisciplinary pain management program for the treatment of chronic pelvic pain. Pain. 1990;41(1):41-6. X-3. [pmid: 2352765].
1067 Schlaff WD, et al. Megestrol acetate for treatment of endometriosis. Obstet Gynecol. 1990;75(4):646-8. X-3. [pmid: 2314784].
1068 Stovall TG, Ling FW, Crawford DA. Hysterectomy for chronic pelvic pain of presumed uterine etiology. Obstet Gynecol. 1990;75(4):676-9. X-3. [pmid: 2248635].
1069 Gambone JC, Reiter RC. Nonsurgical management of chronic pelvic pain: a multidisciplinary approach. Clin Obstet Gynecol. 1990;33(1):205-11. X-3, X-4, X-5. [pmid: 2311316].
1070 Chronic pelvic pain. Clin Obstet Gynecol. 1990;33(1):117-212. X-1, X-2, X-3, X-4, X-5. [pmid: 2311315].
1071 Reiter RC, Gambone JC. Demographic and historic variables in women with idiopathic chronic pelvic pain. Obstet Gynecol. 1990;75(3 Pt 1):428-32. X-4, X-5. [pmid: 2304712].
1072 Zorn JR, et al. Treatment of endometriosis with a delayed release preparation of the agonist D-Trp6-luteinizing hormone-releasing hormone: long-term follow-up in a series of 50 patients. Fertil Steril. 1990;53(3):401-6. X-2, X-3, X-4, X-5. [pmid: 2137792].
1073 Shaw RW. Nafarelin in the treatment of pelvic pain caused by endometriosis. Am J Obstet Gynecol. 1990;162(2):574-6. X-2, X-3. [pmid: 2137972].
1074 Caterino-de-Araujo A, de-los-Santos Fortuna E. Seropositivity to Chlamydia trachomatis in prostitutes: relationship to other sexually transmitted diseases (STDs). Braz J Med Biol Res. 1990;23(8):697-700. X-2, X-3, X-4. [pmid: 2101095].
1075 Hazlina NNH, et al. A study on common sexually transmitted disease infection in infertile female attending to infertility clinic in HUSM, Kota Bharu, Kelantan. International Medical Journal. 2005;12(3):205-211. X-2, X-3, X-4, X-5.
1076 Kaya B, et al. Anxiety, depression and sexual dysfunction in women with chronic pelvic pain. Sexual & Relationship Therapy. 2006;21(2):187-196. X-3.
1077 Strzempko F. Beyond the pelvis: living with chronic pelvic pain…. 35th Annual Communicating Nursing Research Conference/16th Annual WIN Assembly, “Health Disparities: Meeting the Challenge,”. April 18-20, 2002. Palm Springs, California. Communicating Nursing Research. 2002;35:401-401. X-1, X-2, X-3, X-4.
1078 McGowan L, Pitts M, Carter DC. Chronic pelvic pain: the general practitioner's perspective. Psychology, Health & Medicine. 1999;4(3):303-317. X-2, X-3, X-4, X-5.
1079 Neville C, et al. Comparison of PT and MD findings of physical examination of patients with and without chronic pelvic pain. Journal of Women's Health Physical Therapy. 2009;33(1):16-16. X-4.
1080 Jarrell J. Gynecological pain, endometriosis, visceral disease, and the viscero-somatic connection…. MYOPAIN 2007, the International Congress of the International MYOPAIN Society [IMS]. Washington DC. August 20-23, 2007. Journal of Musculoskeletal Pain. 2008;16(1-2):21-27. X-4.
1081 Fonstad P, Hooper RA. Hip labral tears as a co-morbidity of low back and pelvic girdle pain following motor vehicle collisions: a case series. Journal of Back & Musculoskeletal Rehabilitation. 2008;21(4):245-251. X-3, X-4.
1082 Marx S. ICAOR 2006: does osteopathic treatment have an influence on the symptoms of patients with chronic prostatitis/chronic pelvic pain syndrome (CPPS)? A randomized controlled trial. International Journal of Osteopathic Medicine. 2006;9(1):44-44. X-2, X-4.
1083 Muneyyirci-Delale O, Jalou S. Long-term treatment of symptomatic endometriosis with norethindrone acetate. Clinical Journal of Women's Health. 2001;1(2):69-75. X-3.
1084 Neville C, et al. Musculoskeletal dysfunction in female chronic pelvic pain: a blinded study of examination findings. Journal of Women's Health Physical Therapy. 2009;33(1):20-21. X-2, X-3, X-4, X-5.
1085 Mattsson M, et al. Physiotherapy as empowerment -- treating women with chronic pelvic pain. Advances in Physiotherapy. 2000;2(3):125-143. X-3.
1086 Badillo SA, et al. Randomized multicenter pilot trial shows benefit of manual physical therapies in treatment of urologic chronic pelvic pain. Journal of Women's Health Physical Therapy. 2009;33(1):23-23. X-2, X-3, X-4.
1087 Warwick R, et al. Social support for women with chronic pelvic pain: what is helpful from whom?. Psychology & Health. 2004;19(1):117-134. X-3, X-4.
1088 Yudenfreund-Sujka SM. The association of chronic headaches and fibromyalgia with sexual assault and abuse. American Journal of Pain Management. 2003;13(1):29-32. X-1, X-2, X-3, X-4.
1089 Hawk C, Long CR. Use of a pilot to refine the design of a study to develop a manual placebo treatment. JNMS: Journal of the Neuromusculoskeletal System. 2000;8(2):39-48. X-2, X-3, X-4.
1090 Wong GCH, et al. Uterine artery embolization: a minimally invasive technique for the treatment of uterine fibroids. Journal of Women's Health & Gender-Based Medicine. 2000;9(4):357-362. X-1, X-2, X-3, X-4.
1091 Denny E. ‘You are one of the unlucky ones’: delay in the diagnosis of endometriosis. Diversity in Health & Social Care. 2004;1(1):39-44. X-3, X-4.
1092 Guo SW. Recurrence of endometriosis and its control. Human Reproduction Update. 2009;15(4):441-461. X-1, X-2, X-3, X-4. [pmid: 19279046].
1093 Pontari M. Chronic Prostatitis/Chronic Pelvic Pain: The Disease. Journal of Urology. 2009;182(1):19-20. X-1, X-2, X-3, X-4. [pmid: 19467677].
1094 Nickel JC. Chronic Prostatitis/Chronic Pelvic Pain: The Syndrome. Journal of Urology. 2009;182(1):18-19. X-1, X-2, X-3, X-4. [pmid: 19447420].
1095 Cawich SO, et al. Management of obstetric anal sphincter injuries at the University Hospital of the West Indies. West Indian Medical Journal. 2008;57(5):482-485. X-3, X-4. [pmid: 19565979].
1096 Claerhout F, et al. Medium-Term Anatomic and Functional Results of Laparoscopic Sacrocolpopexy Beyond the Learning Curve. European Urology. 2009;55(6):1459-1468. X-2, X-3, X4, X-5. [pmid: 19111382].
1097 Allen JA, Phillips K. Pelvic pain following microwave endometrial ablation-is hysteroscopic adhesiolysis worthwhile?. Gynecological Surgery. 2009;6(2):101-104. X-3.
1098 Fenton BW, et al. A preliminary study of transcranial direct current stimulation for the treatment of refractory chronic pelvic pain. Brain Stimulation. 2009;2(2):103-107. X-3. [pmid: 20633407].
1099 Chen L, et al. Altered quantitative sensory testing outcome in subjects with opioid therapy. Pain. 2009;143(1-2):65-70. X-2, X-3, X-4. [pmid: 19237249].
1100 Forcier M. Emergency Department Evaluation of Acute Pelvic Pain in the Adolescent Female. Clinical Pediatric Emergency Medicine. 2009;10(1):20-30. X-1, X-2, X-3, X-4.
1101 Steers WD. This Month in Adult Urology. Journal of Urology. 2009;181(3):935-937. X-1, X-2, X-3, X-4, X-5.
1102 Li CY, et al. Management of ureteral endometriosis: A report of ten cases. Chinese Medical Sciences Journal. 2008;23(4):218-223. X-3. [pmid: 19180882].
1103 Levy MH, Chwistek M, Mehta RS. Management of chronic pain in cancer survivors. Cancer Journal. 2008;14(6):401-409. X-1, X-2, X-3, X-4, X-5.
1104 Oakeshott P, et al. Community-based trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: The POPI (prevention of pelvic infection) trial. Trials. 2008;9(73). X-1, X-2, X-3, X-4, X-5.
1105 Stones W. Medical management of chronic pelvic pain. Obstetrics, Gynaecology and Reproductive Medicine. 2008;18(9):233-235. X-3.
1106 Furuya R, et al. New classification of midline cysts of the prostate in adults via a transrectal ultrasonography-guided opacification and dye-injection study. BJU International. 2008;102(4):475-478. X-2, X-3, X-4. [pmid: 18284411].
1107 Kalu E, McAuley W, Richardson R. Teenagers, adolescents, endometriosis and recurrence: A retrospective analysis of recurrence following primary operative laparoscopy. Gynecological Surgery. 2008;5(3):209-212. X-3.
1108 Vermaas M, et al. Reirradiation, surgery and IORT for recurrent rectal cancer in previously irradiated patients. Radiotherapy and Oncology. 2008;87(3):357-360. X-2, X-3, X-4. [pmid: 18353474].
1109 Deer T, Masone RJ. Selection of spinal cord stimulation candidates for the treatment of chronic pain. Pain Medicine. 2008;9(SUPPL. 1):S82-S92. X-1, X-2, X-3.
1110 Williams CP, et al. Clinical results of intraoperative radiation therapy for patients with locally recurrent and advanced tumors having colorectal involvement. American Journal of Surgery. 2008;195(3):405-409. X-2, X-3, X-4. [pmid: 18241835].
1111 Wallace RB, et al. Application of FDA adverse event report data to the surveillance of dietary botanical supplements. Annals of Pharmacotherapy. 2008;42(5):653-660. X-2, X-3, X-4. [pmid: 18397972].
1112 Avins AL, et al. A detailed safety assessment of a saw palmetto extract. Complementary Therapies in Medicine. 2008;16(3):147-154. X-2, X-3, X-4. [pmid: 18534327].
1113 Pontari MA, Ruggieri MR. Mechanisms in Prostatitis/Chronic Pelvic Pain Syndrome. Journal of Urology. 2008;179(5 SUPPL):S61-S67. X-1, X-2, X-3, X-4. [pmid: 18405756].
1114 Brown S. Prescribing flexibility through prescription compounding. Techniques in Regional Anesthesia and Pain Management. 2008;12(2):119-121. X-1, X-2, X-3, X-4.
1115 Schneider J, et al. EMDR in the treatment of chronic phantom limb pain. Pain Medicine. 2008;9(1):76-82. X-2, X-3, X-4. [pmid: 18254770].
1116 Brandsborg B, et al. Chronic pain after hysterectomy. Acta Anaesthesiologica Scandinavica. 2008;52(3):327-331. X-1, X-2, X-3, X-4. [pmid: 18269384].
1117 Narang S, et al. Efficacy of Dronabinol as an Adjuvant Treatment for Chronic Pain Patients on Opioid Therapy. Journal of Pain. 2008;9(3):254-264. X-3. [pmid: 18088560].
1118 Check JH, et al. A disorder of sympathomimetic amines leading to increased vascular permeability may be the etiologic factor in various treatment refractory health problems in women. Medical Hypotheses. 2008;70(3):671-677. X-1, X-2, X-3, X-4. [pmid: 17765403].
1119 Van Buyten JP. Radiofrequency or neuromodulation treatment of chronic pain, when is it useful?. European Journal of Pain Supplements. 2008;2(1):57-66. X-1, X-2, X-3.
1120 Wuest J, et al. Chronic Pain in Women Survivors of Intimate Partner Violence. Journal of Pain. 2008;9(11):1049-1057. X-2, X-3, X-4. [pmid: 18701353].
1121 Lefevre JH, et al. Radiofrequency ablation for recurrent pelvic cancer. Colorectal Disease. 2008;10(8):781-784. X-3. [pmid: 18028468].
1122 Falowski S, Celii A, Sharan A. Spinal Cord Stimulation: An Update. Neurotherapeutics. 2008;5(1):86-99. X-1, X-2, X-3, X-4. [pmid: 18164487].
1123 El Makhzangy H, et al. Response to pegylated interferon alfa-2a and ribavirin in chronic hepatitis C genotype 4. Journal of Medical Virology. 2009;81(9):1576-1583. X-4. [pmid: 19626613].
1124 Vercellini P, et al. Chronic pelvic pain in women: Etiology, pathogenesis and diagnostic approach. Gynecological Endocrinology. 2009;25(3):149-158. X-1, X-2, X-3, X-4. [pmid: 19347704].
1125 Abbott J. Gynecological indications for the use of botulinum toxin in women with chronic pelvic pain. Toxicon. 2009;54(5):647-653. X-1, X-2, X-3, X-4, X-5. [pmid: 19264089].
1126 Martino M, et al. Short and long-term safety of lenograstim administration in healthy peripheral haematopoietic progenitor cell donors: A single centre experience. Bone Marrow Transplantation. 2009;44(3):163-168. X-2, X-3, X-4. [pmid: 19182833].
1127 Pannek J, Einig EM, Einig W. Clinical management of bladder dysfunction caused by sexual abuse. Urologia Internationalis. 2009;82(4):420-425. X-2, X-3, X-4. [pmid: 19506409].
1128 Finamore PS, Goldstein HB, Whitmore KE. Pelvic floor muscle dysfunction: A review. Journal of Pelvic Medicine and Surgery. 2008;14(6):417-422. X-1, X-2, X-3, X-4.
1129 Cura M, Cura A. What is the significance of ovarian vein reflux detected by computed tomography in patients with pelvic pain?. Clinical Imaging. 2009;33(4):306-310. X-1, X-3, X-4, X-5. [pmid: 19559354].
1130 Baka S, et al. Prevalence of Ureaplasma urealyticum and Mycoplasma hominis in Women With Chronic Urinary Symptoms. Urology. 2009;74(1):62-66. X-2, X-3, X-4. [pmid: 19371925].
1131 Seracchioli R, et al. Post-operative use of oral contraceptive pills for prevention of anatomical relapse or symptom-recurrence after conservative surgery for endometriosis. Human Reproduction. 2009;24(11):2729-2735. X-1, X-2, X-3. [pmid: 19625310].
1132 Cicin I, et al. Yolk sac tumours of the ovary: Evaluation of clinicopathological features and prognostic factors. European Journal of Obstetrics Gynecology and Reproductive Biology. 2009;146(2):210-214. X-2, X-3, X-4.
1133 Bellingham GA, Peng PWH. Ultrasound-guided interventional procedures for chronic pelvic pain. Techniques in Regional Anesthesia and Pain Management. 2009;13(3):171-178. X-1, X-2, X-3, X-4.
1134 Bottomley C, Bourne T. Diagnosis and management of ovarian cyst accidents. Best Practice and Research: Clinical Obstetrics and Gynaecology. 2009;23(5):711-724. X-1, X-2, X-3, X-4, X-5. [pmid: 19299205].
1135 Brill AI. Treatment of fibroids via uterine artery occlusion (uterine artery embolization and Doppler-guided uterine artery occlusion): Potential role in today's armamentarium. Archives of Gynecology and Obstetrics. 2009;280(4):513-520. X-1, X-2, X-3, X-4. [pmid: 19205712].
1136 Leone P, et al. One-day famciclovir vs. placebo in patient-initiated episodic treatment of recurrent genital herpes in immunocompetent Black patients. Current Medical Research and Opinion. 2010;26(3):653-661. X-2, X-3, X-4, X-5. [pmid: 20070143].
1137 Sadeghi-Nejad H, et al. Sexually transmitted diseases and sexual function. Journal of Sexual Medicine. 2010;7(1 PART 2):389-413. X-1, X-2, X-3, X-4. [pmid: 20092446].
1138 Andersson KE. This Month in Investigative Urology. Journal of Urology. 2009;182(5):2096-2098. X-1, X-2, X-3, X-4, X-5. [pmid: 19765745].
1139 Barbosa CP, et al. OC-125 immunostaining in endometriotic lesion samples. Archives of Gynecology and Obstetrics. 2010;281(1):43-47. X-3, X-4, X-5. [pmid: 19363680].
1140 Chrubasik S, et al. Patient-perceived benefit during one year of treatment with Doloteffin<sup></sup>. Phytomedicine. 2007;14(6):371-376. X-2, X-3, X-4. [pmid: 17521896].
1141 Anast JW, Andriole GL, Grubb IRL. Managing the local complications of locally advanced prostate cancer. Current Urology Reports. 2007;8(3):211-216. X-2, X-3, X-4. [pmid: 17459270].
1142 Whitmore K, Siegel JF, Kellogg-Spadt S. Interstitial cystitis/painful bladder syndrome as a cause of sexual pain in women: A diagnosis to consider. Journal of Sexual Medicine. 2007;4(3):720-727. X-1, X-2, X-3, X-4. [pmid: 17498107].
1143 Veras E, et al. Ovarian nonsmall cell neuroendocrine carcinoma: A clinicopathologic and immunohistochemical study of 11 cases. American Journal of Surgical Pathology. 2007;31(5):774-782. X-2, X-3, X-4. [pmid: 17460463].
1144 Forrest JB, Nickel JC, Moldwin RM. Chronic Prostatitis/Chronic Pelvic Pain Syndrome and Male Interstitial Cystitis: Enigmas and Opportunities. Urology. 2007;69(4 SUPPL):S60-S63. X-1, X-2, X-3, X-4.
1145 Nazif O, Teichman JMH, Gebhart GF. Neural Upregulation in Interstitial Cystitis. Urology. 2007;69(4 SUPPL):S24-S33. X-1, X-2, X-3, X-4, X-5.
1146 Stanford EJ, Dell JR, Parsons CL. The Emerging Presence of Interstitial Cystitis in Gynecologic Patients with Chronic Pelvic Pain. Urology. 2007;69(4 SUPPL):S53-S59. X-1, X-2, X-3, X-4.
1147 Lin WY, et al. Preliminary study of electric stimulation on premature ejaculation in patients with chronic pelvic pain syndrome or chronic prostatitis. Sexologies. 2007;16(1):38-42. X-2, X-3, X-4.
1148 Remorgida V, et al. Letrozole and norethisterone acetate in rectovaginal endometriosis. Fertility and Sterility. 2007;88(3):724-726. X-3. [pmid: 17331508].
1149 van Goor H. Consequences and complications of peritoneal adhesions. Colorectal Disease. 2007;9(SUPPL. 2):25-34. X-1, X-2, X-3, X-4. [pmid: 17824967].
1150 Alshab AK, Goldner JD, Panchal SJ. Complications of sympathetic blocks for visceral pain. Techniques in Regional Anesthesia and Pain Management. 2007;11(3):152-156. X-1, X-2, X-3, X-4, X-5.
1151 Remorgida V, et al. Letrozole and desogestrel-only contraceptive pill for the treatment of stage IV endometriosis. Australian and New Zealand Journal of Obstetrics and Gynaecology. 2007;47(3):222-225. X-3. [pmid: 17550490].
1152 Check JH, et al. The treatment of idiopathic edema, a cause of chronic pelvic pain in women: Effectively controlled chronic refractory urticaria - Case reports. Clinical and Experimental Obstetrics and Gynecology. 2006;33(3):183-184. X-3.
1153 Adamson GD. Control of chronic pelvic pain. Journal of Minimally Invasive Gynecology. 2006;13(6):578-582. X-1, X-2, X-3, X-4. [pmid: 17097583].
1154 Santillo VM, Lowe FC. The management of chronic prostatitis in men with HIV. Current Prostate Reports. 2006;4(2):93-99. X-1, X-2, X-3, X-4.
1155 Wilder-Smith CH. Predicting pain and pain responses to opioids. European Journal of Pain Supplements. 2007;1(1):31-37. X-1, X-2, X-3.
1156 Dent A, King CH. Schistosoma haematobium: The urinary parasite. Infections in Medicine. 2007;24(11):489-496. X-1, X-2, X-3, X-4, X-5.
1157 Shen B, et al. Effect of withdrawal of nonsteroidal anti-inflammatory drug use on ileal pouch disorders. Digestive Diseases and Sciences. 2007;52(12):3321-3328. X-2, X-3, X-4. [pmid: 17410449].
1158 Planner AC, et al. Picture quiz. Imaging. 2006;18(4):278-285. X-1, X-2, X-3.
1159 Theoharides TC, O'Leary M. Painful bladder syndrome/interstitial cystitis: Current concepts and role of nutraceuticals. Seminars in Preventive and Alternative Medicine. 2006;2(1):6-14. X-1, X-2, X-3, X-4.
1160 Peters KM, Carrico DJ. Frequency, urgency, and pelvic pain: Treating the pelvic floor versus the epithelium. Current Urology Reports. 2006;7(6):450-455. X-1, X-2, X-3, X-4, X-5. [pmid: 17052440].
1161 Johnson N. Management of dysmenorrhoea. Reviews in Gynaecological and Perinatal Practice. 2006;6(1-2):57-62. X-1, X-2, X-3.
1162 Khan ZE, Rizvi JH. Pelvic inflammatory disease and pelvic abscesses. Reviews in Gynaecological and Perinatal Practice. 2006;6(3-4):185-191. X-1, X-2, X-3, X-4.
1163 Colombel M, et al. The Effect of Ofloxacin on Bacillus Calmette-Guerin Induced Toxicity in Patients With Superficial Bladder Cancer: Results of a Randomized, Prospective, Double-Blind, Placebo Controlled, Multicenter Study. Journal of Urology. 2006;176(3):935-939. X-2, X-3, X-4, X-5. [pmid: 16890660].
1164 Nijs P. Sexual dysfunctions in women with chronic pelvic pain. A modified sex-therapeutic model. Sexologies. 2006;15(2):121-125. X-1, X-2, X-3.
1165 Ikuta A, et al. Management of transvaginal ultrasound-guided absolute ethanol sclerotherapy for ovarian endometriotic cysts. Journal of Medical Ultrasonics. 2006;33(2):99-103. X-3.
1166 Calvillo O, Guevara U, Chahadeh H. Neuroaugmentation in the management of pelvic pain syndromes. Techniques in Regional Anesthesia and Pain Management. 2006;10(1):7-11. X-1, X-2, X-3, X-4.
1167 Fassiadis N. Treatment for pelvic congestion syndrome causing pelvic and vulvar varices. International Angiology. 2006;25(1):1-3. X-1, X-2, X-3, X-4, X-5. [pmid: 16520716].
1168 Evans RJ, Stanford EJ. Current issues in the diagnosis of painful bladder syndrome/interstitial cystitis. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 2006;51(3 SUPPL):241-252. X-1, X-2, X-3, X-4, X-5. [pmid: 16676919].
1169 Tettambel MA. An osteopathic approach to treating women with chronic pelvic pain. Journal of the American Osteopathic Association. 2005;105(9 SUPPL. 4):S20-S22. X-1, X-2, X-3. [pmid: 16249362].
1170 Victor L, Richeimer SH. Trustworthiness as a clinical variable: The problem of trust in the management of chronic, nonmalignant pain. Pain Medicine. 2005;6(5):385-391. X-1, X-2, X-3, X-4. [pmid: 16266360].
1171 Fauconnier A, Chapron C. Endometriosis and pelvic pain: Epidemiological evidence of the relationship and implications. Human Reproduction Update. 2005;11(6):595-606. X-1, X-2, X-3, X-4. [pmid: 16172113].
1172 Plancarte-Sanchez R, Guajardo-Rosas J, Guillen-Nunez R. Superior hypogastric plexus block and ganglion impar (Walther). Techniques in Regional Anesthesia and Pain Management. 2005;9(2 SPEC. ISS):86-90. X-1, X-2, X-3, X-4, X-5.
1173 Andriole VT, Haverstock DC, Choudhri SH. Retrospective analysis of the safety profile of oral moxifloxacin in elderly patients enrolled in clinical trials. Drug Safety. 2005;28(5):443-452. X-2, X-3, X-4. [pmid: 15853445].
1174 Benoit L, et al. The role of surgery and treatment trends in uterine sarcoma. European Journal of Surgical Oncology. 2005;31(4):434-442. X-2, X-3, X-4, X-5. [pmid: 15837053].
1175 Marsh EE, Laufer MR. Endometriosis in premenarcheal girls who do not have an associated obstructive anomaly. Fertility and Sterility. 2005;83(3):758-760. X-2, X-3. [pmid: 15749511].
1176 Mulligan K, et al. Effect of nandrolone decanoate therapy on weight and lean body mass in HIV-infected women with weight loss: A randomized, double-blind, placebo-controlled, multicenter trial. Archives of Internal Medicine. 2005;165(5):578-585. X-2, X-3, X-4. [pmid: 15767536].
1177 Jagannath S, et al. Bortezomib in recurrent and/or refractory multiple myeloma: Initial clinical experience in patients with impaired renal function. Cancer. 2005;103(6):1195-1200. X-2, X-3, X-4, X-5. [pmid: 15690325].
1178 Chertok IR, et al. Implications of endometriosis for women who observe Jewish law (halakha). Israel Medical Association Journal. 2005;7(2):71-74. X-1, X-2, X-3, X-4. [pmid: 15729953].
1179 Nordling J. Pelvic pain and interstitial cystitis: Therapeutic strategies, results and limitations. EAU Update Series. 2004;2(4 SPEC.ISS):179-186. X-1, X-2, X-3, X-4.
1180 Schurch B, Reitz A. Botox in urology: A new treatment modality without limitations?. EAU Update Series. 2004;2(4 SPEC.ISS):170-178. X-1, X-2, X-3, X-4.
1181 Chronic prostatitis/chronic pelvic pain syndrome: Still lots to learn about its aetiology, evaluation and treatment. Drugs and Therapy Perspectives. 2004;20(11):11-14. X-2, X-3, X-4.
1182 Rousseau ME, Gottlieb SF. Pain at midlife. Journal of Midwifery and Women's Health. 2004;49(6):529-538. X-1, X-2, X-3, X-4.
1183 McColl WF, Smith T, Aberg C. Pain in women's health: A multi-faceted approach toward understanding. Journal of Midwifery and Women's Health. 2004;49(6):473-481. X-1, X-2, X-3.
1184 Jones I. A GP's guide to pelvic inflammatory disease. Medicine Today. 2004;5(9):35-38. X-1, X-2, X-3, X-4.
1185 Valentin L. Transvaginal sonography in gynaecology. Reviews in Gynaecological Practice. 2004;4(1):50-57. X-1, X-2, X-3, X-4.
1186 Cobellis L, et al. A danazol-loaded intrauterine device decreases dysmenorrhea, pelvic pain, and dyspareunia associated with endometriosis. Fertility and Sterility. 2004;82(1):239-240. X-3. [pmid: 15237024].
1187 Holland-Hall CM, Brown RT. Evaluation of the adolescent with chronic abdominal or pelvic pain. Journal of Pediatric and Adolescent Gynecology. 2004;17(1):23-27. X-1, X-2, X-3. [pmid: 15010035].
1188 Hough DM, et al. Chronic perineal pain caused by pudendal nerve entrapment: Anatomy and CT-guided perineural injection technique. American Journal of Roentgenology. 2003;181(2):561-567. X-1, X-2, X-3, X-4, X-5. [pmid: 12876048].
1189 Yang J, et al. Endometriosis in adolescents - Analysis of 6 cases. Chinese Medical Sciences Journal. 2003;18(1):63-66. X-2, X-3, X-4. [pmid: 12901532].
1190 Horowitz S. NIH funds key studies in acupuncture and TCM. Alternative and Complementary Therapies. 2003;9(1):11-15. X-1, X-2, X-3, X-4, X-5.
1191 Nadler RB, et al. Bladder training biofeedback and pelvic floor myalgia. Urology. 2002;60(6 SUPPL. A):42-44. X-3. [pmid: 12521595].
1192 Pontari MA, et al. Inflammation and anti-inflammatory therapy in chronic prostatitis. Urology. 2002;60(6 SUPPL. A):29-34. X-1, X-2, X-3, X-4. [pmid: 12521589].
1193 Datta NS, et al. Role of alpha-blockers in the treatment of chronic prostatitis. Urology. 2002;60(6 SUPPL. A):27-28. X-1, X-2, X-3, X-4. [pmid: 12521587].
1194 Rafique M, Arif MH. Management of iatrogenic ureteric injuries associated with gynecological surgery. International Urology and Nephrology. 2002;34(1):31-35. X-2, X-3, X-4. [pmid: 12549636].
1195 Aubuchon M, Pinto AB, Williams DB. Treatment of uterine fibroids. Primary Care Update for Ob/Gyns. 2002;9(6):231-237. X-1, X-2, X-3, X-4, X-5.
1196 Frederick J, et al. Operative morbidity and reproductive outcome in secondary myomectomy: A prospective cohort study. Human Reproduction. 2002;17(11):2967-2971. X-2, X-3, X-4, X-5. [pmid: 12407058].
1197 Gambone JC, et al. Consensus statement for the management of chronic pelvic pain and endometriosis: Proceedings of an expert-panel consensus process. Fertility and Sterility. 2002;78(5):961-972. X-1, X-2, X-3, X-4. [pmid: 12413979].
1198 Teirney R, Fraser IS. How to recognise and manage endometriosis. Medicine Today. 2002;3(8):30-37. X-1, X-2, X-3, X-4.
1199 Luzzi GA. Chronic prostatitis and chronic pelvic pain in men: Aetiology, diagnosis and management. Journal of the European Academy of Dermatology and Venereology. 2002;16(3):253-256. X-1, X-2, X-3, X-4. [pmid: 12195565].
1200 Belsey J. Primary care workload in the management of chronic pain: A retrospective cohort study using a GP database to identify resource implications for UK primary care. Journal of Medical Economics. 2002;5(39-50):39-50. X-2, X-3, X-4, X-5.
1201 Jamal A, Mesdaghinia S. Ruptured corpus luteum cysts and anticoagulant therapy. International Journal of Gynecology and Obstetrics. 2002;76(3):319-320. X-2, X-3, X-4, X-5. [pmid: 11880140].
1202 Potts JM. The four categories of prostatitis: A practical approach to treatment. Cleveland Clinic Journal of Medicine. 2001;68(5). X-1, X-2, X-3, X-4.
1203 Reich H. Issues surrounding surgical menopause: Indications and procedures. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 2001;46(3 SUPPL):297-306. X-1, X-2, X-3, X-4. [pmid: 11304878].
1204 Roque AJ, Srougi M. Chronic pelvic pain syndrome: Urological aspects. Brazilian Journal of Urology. 2001;27(1):60-71. X-1, X-2, X-3, X-4.
1205 Fedele L, et al. Gonadotropin-releasing hormone agonist treatment for endometriosis of the rectovaginal septum. American Journal of Obstetrics and Gynecology. 2000;183(6):1462-1467. X-3. [pmid: 11120511].
1206 Muzii L, et al. Postoperative administration of monophasic combined oral contraceptives after laparoscopic treatment of ovarian endometriomas: A prospective, randomized trial. American Journal of Obstetrics and Gynecology. 2000;183(3):588-592. X-2, X-3, X-4, X-5. [pmid: 10992178].
1207 Naber KG, Weidner W. Chronic prostatitis - An infectious disease?. Journal of Antimicrobial Chemotherapy. 2000;46(2):157-161. X-2, X-3, X-4. [pmid: 10933636].
1208 Friedrich M, et al. Evaluation of the secretion of the atrial natriuretic factor (ANF) after laparotomy. Clinical and Experimental Obstetrics and Gynecology. 2000;27(2):113-115. X-3.
1209 Friedrich M, et al. Atrial natriuretic factor (ANF) after laparoscopy and morphine application for pain therapy. Clinical and Experimental Obstetrics and Gynecology. 2000;27(1):9-11. X-3.
1210 Palter SF. Microlaparoscopy under local anesthesia and conscious pain mapping for the diagnosis and management of pelvic pain. Current Opinion in Obstetrics and Gynecology. 1999;11(4):387-393. X-1, X-2, X-3. [pmid: 10498025].
1211 Scialli AR. Evaluating chronic pelvic pain: A consensus recommendation. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 1999;44(11):945-952. X-1, X-2, X-3, X-4. [pmid: 10589405].
1212 Srivastava A, et al. Nonbacterial prostatitis / prostatodynia - A urodynamic spectrum. Indian Journal of Urology. 1999;15(2):133-136. X-2, X-3, X-4.
1213 Propst AM, Laufer MR. Endometriosis in adolescents: Incidence, diagnosis and treatment. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 1999;44(9):751-758. X-1, X-2, X-3, X-4. [pmid: 10509296].
1214 Shoskes DA, Zeitlin SI. Use of prostatic massage in combination with antibiotics in the treatment of chronic prostatitis. Prostate Cancer and Prostatic Diseases. 1999;2(3):159-162. X-2, X-3, X-4. [pmid: 12496826].
1215 Rock JA, Roberts CP. Management of pelvic pain recurrence: A quality of life issue in endometriosis. Journal of Gynecologic Techniques. 1999;5(2):67-78. X-1, X-2, X-3.
1216 Goodwin SC, Chen G. Uterine artery embolization for uterine fibroids. Contemporary Reviews in Obstetrics and Gynaecology. 1998;10(3):217-221. X-1, X-2, X-3.
1217 Miller JD, et al. Historical prospective cohort study of the recurrence of pain after discontinuation of treatment with danazol or a gonadotropin-releasing hormone agonist. Fertility and Sterility. 1998;70(2):293-296. X-3. [pmid: 9696224].
1218 Doyle DF, Li TC, Richmond MN. The prevalence of continuing chronic pelvic pain following a negative laparoscopy. Journal of Obstetrics and Gynaecology. 1998;18(3):252-255. X-3. [pmid: 15512071].
1219 Babarinsa IA, et al. Daycare diagnostic laparoscopy: Experience with the first 1000 patients in a tropical gynaecological service. Gynaecological Endoscopy. 1997;6(5):273-276. X-2, X-3, X-4, X-5.
1220 Federici D, et al. Pain relief after combined medical and laparoscopic conservative treatment of stage Ill-IV endometriosis: A comparison with medical therapy. Minimally Invasive Therapy and Allied Technologies. 1996;5(6):547-554. X-3.
1221 Messing MJ. Infectious complications after gynecologic surgery. Clinical Consultations in Obstetrics and Gynecology. 1996;8(2):62-68. X-3.
1222 Carey MP, Slack MC. GnRH analogue in assessing chronic pelvic pain in women with residual ovaries. British Journal of Obstetrics and Gynaecology. 1996;103(2):150-153. X-3. [pmid: 8616132].
1223 Carter JE, Trotter JP. GnRH analogs in the treatment of endometriosis: Clinical and economic considerations. Female Patient OB/GYN Edition. 1995;20(12):13-14. X-1, X-2, X-3, X-4.
1224 Paix A, et al. Subcutaneous fentanyl and sufentanil infusion substitution for morphine intolerance in cancer pain management. Pain. 1995;63(2):263-269. X-2, X-3, X-4. [pmid: 8628593].
1225 Broadhurst NA. Pelvic dysfunction. Journal of Neurological and Orthopaedic Medicine and Surgery. 1994;15(3):127-129. X-2, X-3, X-4, X-5.
1226 Abuchaibe O, et al. Intraoperative radiotherapy in locally advanced recurrent colorectal cancer. International Journal of Radiation Oncology Biology Physics. 1993;26(5):859-867. X-2, X-3, X-4, X-5.
1227 Friedman AJ, et al. A prospective, randomized trial of gonadotropin-releasing hormone agonist plus estrogen-progestin or progestin ‘add-back’ regimens for women with leiomyomata uteri. Journal of Clinical Endocrinology and Metabolism. 1993;76(6):1439-1445. X-2, X-3, X-4, X-5. [pmid: 8501148].
1228 Summitt RL, Ling FW. Urethral syndrome presenting as chronic pelvic pain. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):77-86. X-3.
1229 Ahmed MS, et al. Serum beta-endorphin levels in chronic pelvic pain patients. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):39-52. X-3, X-4, X-5.
1230 Siegel SW. Evaluation and treatment of interstitial cystitis. Problems in Urology. 1991;5(1):183-193. X-1, X-2, X-3, X-4.
1231 ter Kuile MM, Weijenborg PTM, Spinhoven P. Sexual functioning in women with chronic pelvic pain: The role of anxiety and depression. Journal of Sexual Medicine. 2010;7(5):1901-1910. X-4, X-5. [pmid: 19678881].
1232 Kahn BS, et al. Prevalence of interstitial cystitis in vulvodynia patients detected by bladder potassium sensitivity. Journal of Sexual Medicine. 2010;7(2, Pt 2):996-1002. X-2, X-3, X-4, X-5. [pmid: 19845546].
1233 Paras ML, et al. Sexual abuse and lifetime diagnosis of somatic disorders: A systematic review and meta-analysis. JAMA: Journal of the American Medical Association. Special Issue: Violence and human rights. 2009;302(5):550-561. X-1, X-2, X-3, X-4.
1234 Davis SNP, Binik YM, Carrier S. Sexual dysfunction and pelvic pain in men: A male sexual pain disorder?. Journal of Sex & Marital Therapy. 2009;35(3):182-205. X-2, X-3, X-4. [pmid: 19360518].
1235 Buffington CAT. Developmental influences on medically unexplained symptoms. Psychotherapy and Psychosomatics. 2009;78(3):139-144. X-1, X-2, X-3, X-4. [pmid: 19270468].
1236 Wickramasekera I II. Review of Paradoxical hypnotic experiences in escaping constraining dilemmas: A clinical example. American Journal of Clinical Hypnosis. 2009;51(3):311. X-1, X-2, X-3, X-4.
1237 Tschugguel W, Hunter ME. Paradoxical hypnotic experiences in escaping constraining dilemmas: A clinical example. International Journal of Clinical and Experimental Hypnosis. 2008;56(4):373-383. X-3. [pmid: 18726803].
1238 Hiemstra E, Weijenborg PTM, Jansen FW. Management of chronic pelvic pain additional to tubal sterilization. Journal of Psychosomatic Obstetrics & Gynecology. 2008;29(3):153-156. X-3. [pmid: 18608819].
1239 Jeynes LC, Gauci CA. Evidence for the use of botulinum toxin in the chronic pain setting—A review of the literature. Pain Practice. 2008;8(4):269-276. X-1, X-2, X-3. [pmid: 18503628].
1240 Riedl A, et al. Somatic comorbidities of irritable bowel syndrome: A systematic analysis. Journal of Psychosomatic Research. 2008;64(6):573-582. X-1, X-2, X-3, X-5. [pmid: 18501257].
1241 Chelli D, et al. Actinomycose pelvienne expérience Tunisienne: À propos de 5 cas. Pelvic actinomycosis in Tunisia: Five cases. Cahiers D'Études et De Recherche Francophone/ Santé. 2008;18(2):77-82. X-3, X-4.
1242 Shaver JLF. Sleep disturbed by chronic pain in fibromyalgia, irritable bowel, and chronic pelvic pain syndromes. Sleep Medicine Clinics. 2008;3(1):47-60. X-1, X-2, X-3.
1243 Rosenbaum TY, Owens A. The role of pelvic floor physical therapy in the treatment of pelvic and genital pain-related sexual dysfunction. Journal of Sexual Medicine. 2008;5(3):513-523. X-1, X-2, X-3, X-4. [pmid: 18304280].
1244 Romans S, Cohen M. Unexplained and underpowered: The relationship between psychosomatic disorders and interpersonal abuse--A critical review. Harvard Review of Psychiatry. 2008;16(1):35-54. X-1, X-2, X-3, X-4. [pmid: 18306098].
1245 Mayer RD, Howard FM. Sacral nerve stimulation: Neuromodulation for voiding dysfunction and pain. Neurotherapeutics. 2008;5(1):107-113. X-1, X-2, X-3, X-4, X-5. [pmid: 18164489].
1246 LaFrance WC Jr. Treating patients with functional symptoms: One size does not fit all. Journal of Psychosomatic Research. 2007;63(6):633-635. X-1, X-2, X-3, X-4, X-5. [pmid: 18061754].
1247 Evans S, Moalem-Taylor G, Tracey DJ. Pain and endometriosis. Pain. 2007;132(Suppl 1):S22-S25. X-1, X-2, X-3, X-4. [pmid: 17761388].
1248 Roelofs K, Spinhoven P. Trauma and medically unexplained symptoms: Towards an integration of cognitive and neuro-biological accounts. Clinical Psychology Review. 2007;27(7):798-820. X-1, X-2, X-3, X-4. [pmid: 17728032].
1249 Lydiard RB. Irritable bowel syndrome: Stress and distress. Primary Psychiatry. 2007;14(4):38-39. X-1, X-2, X-3, X-4, X-5.
1250 Tanriverdi F, et al. The hypothalamo-pituitary-adrenal axis in chronic fatigue syndrome and fibromyalgia syndrome. Stress: The International Journal on the Biology of Stress. 2007;10(1):13-25. X-1, X-2, X-3, X-4.
1251 Chandra PS, Ranjan S. Psychosomatic obstetrics and gynecology - a neglected field?. Current Opinion in Psychiatry. 2007;20(2):168-173. X-1, X-2, X-3, X-4. [pmid: 17278917].
1252 Mowla A, et al. Relief of Acute Intractable Traumatic Pain with ECT. Journal of Psychiatric Practice. 2007;13(1):55-56. X-2, X-3, X-4. [pmid: 17242594].
1253 Luzzi GA, Law LA. The male sexual pain syndromes. International Journal of STD & AIDS. 2006;17(11):720-728. X-1, X-2, X-3, X-4. [pmid: 17062172].
1254 Kapural L, et al. Spinal Cord Stimulation Is an Effective Treatment for the Chronic Intractable Visceral Pelvic Pain. Pain Medicine. 2006;7(5):440-443. X-3. [pmid: 17014604].
1255 Brookoff D, Bennett DS. Neuromodulation in Intractable Interstitial Cystitis and Related Pelvic Pain Syndromes. Pain Medicine. 2006;7(Suppl 1):S166-S184. X-1, X-2, X-3, X-4, X-5.
1256 Latthe P, et al. Factors predisposing women to chronic pelvic pain: systematic review. BMJ: British Medical Journal. 2006;332(7544):749-755. X-1, X-4.
1257 Jackson JL, O'Malley PG, Kroenke K. Antidepressants and cognitive-behavioral therapy for symptom syndromes. CNS Spectrums. 2006;11(3):212-222. X-1, X-2, X-3. [pmid: 16575378].
1258 McKay A. Chlamydia screening programs: A review of the literature. Part 1: Issues in the promotion of chlamydia testing of youth by primary care physicians. Canadian Journal of Human Sexuality. 2006;15(1):1-11. X-1, X-2, X-3, X-4.
1259 Azevedo K, et al. Pain Impacts Sexual Functioning Among Interstitial Cystitis Patients. Sexuality and Disability. 2005;23(4):189-208. X-2, X-3, X-4.
1260 Michalek P, Dutka J. Computed tomography-guided anterior approach to the superior hypogastric plexus for noncancer pelvic pain: A report of two cases. The Clinical Journal of Pain. 2005;21(6):553-556. X-3. [pmid: 16215342].
1261 Berkley KJ. A life of pelvic pain. Physiology & Behavior. Special Issue: Florida State University Special Issue. 2005;86(3):272-280. X-1, X-2, X-3, X-4. [pmid: 16139851].
1262 Zelle BA, et al. Sacroiliac Joint Dysfunction: Evaluation and Management. The Clinical Journal of Pain. 2005;21(5):446-455. X-1, X-2, X-3, X-4. [pmid: 16093751].
1263 Wessely S, et al. There is only one functional somatic syndrome. British Journal of Psychiatry. 2004;185(2):95-96. X-1, X-2, X-3, X-4. [pmid: 15286058].
1264 Grace VM. Embodiment and Meaning Understanding Chronic Pelvic Pain. Journal of Consciousness Studies. 2003;10(11):41-60. X-1, X-2, X-3, X-4.
1265 Luzzi G. Male genital pain disorders. Sexual and Relationship Therapy. 2003;18(2):225-235. X-1, X-2, X-3, X-4.
1266 Turner-Stokes L. Reflex sympathetic dystrophy: A complex regional pain syndrome. Disability and Rehabilitation: An International, Multidisciplinary Journal. 2002;24(18):939-947. X-1, X-2, X-3, X-4.
1267 Talbot M, Bates S. Variability of the symptoms of chronic abacterial prostatitis/chronic pelvic pain syndrome during intermittent therapy with rectal prednisolone foam for ulcerative colitis. International Journal of STD & AIDS. 2001;12(11):752-753. X-2, X-3, X-4. [pmid: 11589817].
1268 Grace V. Critical encounters with the medical paradigm: Encouraging dialogue. Feminism & Psychology. Special Issue: Feminist Psychology in Aotearoa/New Zeland. 2001;11(3):421-428. X-1, X-2, X-3, X-4, X-5.
1269 Nijenhuis ERS. Somatoform dissociation: Major symptoms of dissociative disorders. Journal of Trauma & Dissociation. Special Issue: Somatoform dissociation. 2000;1(4):7-32. X-1, X-2, X-3, X-4, X-5.
1270 Haeringer MT, Dellenbach P. Douleurs pelviennes chroniques. Gynécologue–Psychologue, quels atouts?. Assessment of the physical and psychological aspects of chronic pelvic pain syndrome. European Review of Applied Psychology. Revue Européenne de Psychologie Appliquée. 2000;50(1):97-102. X-6.
1271 Golding JM. Sexual-assault history and long-term physical health problems: Evidence from clinical and population epidemiology. Current Directions in Psychological Science. 1999;8(6):191-194. X-1, X-2, X-3, X-4.
1272 Price JR, Blake F. Chronic pelvic pain: The assessment as therapy. Journal of Psychosomatic Research. 1999;46(1):7-14. X-1, X-2, X-3. [pmid: 10088977].
1273 Bergant AM, Widschwendter M. Chronic pelvic pain (CPP) - gynaecologic and psychosocial factors. Archives of Women's Mental Health. 1998;1(3):103-108. X-1, X-2, X-3.
1274 McGowan LPA, Clark-Carter DD, Pitts MK. Chronic pelvic pain: A meta-analytic review. Psychology & Health. 1998;13(5):937-951. X-1, X-2, X-3.
1275 Ehlert U, Heim C. Verhaltensmedizin bei Frauen mit chronischen Unterbauchbeschwerden. Behavioral medicine for women with chronic pelvis pain. Verhaltenstherapie. 1998;8(2):106-111. X-1, X-2, X-3, X-4.
1276 Knight JA, Green S, Hinson W. Chronic pelvic pain: A systemic approach to assessment and treatment. Families, Systems, & Health. 1997;15(2):135-146. X-3.
1277 Savidge CJ, Slade P. Psychological aspects of chronic pelvic pain. Journal of Psychosomatic Research. 1997;42(5):433-444. X-1, X-2, X-3, X-4. [pmid: 9194016].
1278 Fry RPW, Crisp AH, Beard RW. Sociopsychological factors in chronic pelvic pain: A review. Journal of Psychosomatic Research. 1997;42(1):1-15. X-1, X-2, X-3, X-4. [pmid: 9055210].
1279 Reisner LA. Etiology and management of chronic pelvic pain syndromes. Journal of Pharmaceutical Care in Pain & Symptom Control. 1997;5(4):31-48. X-1, X-2, X-3.
1280 Ehlert U. Differentialdiagnostik und verhaltenstherapeutische Behandlung bei einer Patientin mit chronischen Unterbauchbeschwerden ohne organisches Korrelat. Diagnostic procedures and behavior therapeutic interventions in a patient with pelvic congestion syndrome. Verhaltenstherapie. 1994;4(1):28-37. X-3.
1281 Hagen NA. Sharp, shooting neuropathic pain in the rectum or genitals: Pudendal neuralgia. Journal of Pain and Symptom Management. 1993;8(7):496-501. X-3. [pmid: 7963775].
1282 Glod CA. Long-term consequences of childhood physical and sexual abuse. Archives of Psychiatric Nursing. 1993;7(3):163-173. X-1, X-2, X-3, X-4. [pmid: 8373264].
1283 Seracchioli R, et al. Long-term oral contraceptive pills and postoperative pain management after laparoscopic excision of ovarian endometrioma: a randomized controlled trial. Fertil Steril. 2010;94(2):464-71. X-2, X-3. [pmid: 19442968].
1284 Nolan TE, Elkins TE. Chronic pelvic pain. Differentiating anatomic from functional causes. Postgrad Med. 1993;94(8):125-8. 131. 4. 138. X-1, X-2, X-3, X-4, X-5. [pmid: 8247990].
1285 Hornstein MD, Gleason RE, Barbieri RL. A randomized double-blind prospective trial of two doses of gestrinone in the treatment of endometriosis. Fertil Steril. 1990;53(2):237-41. X-3. [pmid: 2404805].
1286 Worthington M, et al. A randomized comparative study of the metabolic effects of two regimens of gestrinone in the treatment of endometriosis. Fertil Steril. 1993;59(3):522-6. X-3. [pmid: 8458451].
1287 Dlugi AM, Miller JD, Knittle J. Lupron depot (leuprolide acetate for depot suspension) in the treatment of endometriosis: a randomized, placebo-controlled, double-blind study. Lupron Study Group. Fertil Steril. 1990;54(3):419-27. X-2, X-3. [pmid: 2118858].
1288 Kennedy SH, et al. A comparison of nafarelin acetate and danazol in the treatment of endometriosis. Fertil Steril. 1990;53(6):998-1003. X-2, X-3. [pmid: 2140996].
1289 Shaw RW. An open randomized comparative study of the effect of goserelin depot and danazol in the treatment of endometriosis. Zoladex Endometriosis Study Team. Fertil Steril. 1992;58(2):265-72. X-2, X-3. [pmid: 1386029].
1290 Candiani GB, et al. Presacral neurectomy for the treatment of pelvic pain associated with endometriosis: a controlled study. Am J Obstet Gynecol. 1992;167(1):100-3. X-2, X-3. [pmid: 1442906].
1291 Sutton C, Hill D. Laser laparoscopy in the treatment of endometriosis. A 5-year study. Br J Obstet Gynaecol. 1990;97(2):181-5. X-2, X-3. [pmid: 2138497].
1292 Sutton CJ, et al. Prospective, randomized, double-blind, controlled trial of laser laparoscopy in the treatment of pelvic pain associated with minimal, mild, and moderate endometriosis. Fertil Steril. 1994;62(4):696-700. X-2, X-3. [pmid: 7926075].
1293 Hornstein MD, et al. Use of nafarelin versus placebo after reductive laparoscopic surgery for endometriosis. Fertil Steril. 1997;68(5):860-4. X-4. [pmid: 9389816].
1294 Candiani GB, et al. Conservative surgical treatment for severe endometriosis in infertile women: are we making progress?. Obstet Gynecol Surv. 1991;46(7):490-8. X-1, X-2, X-3, X-4. [pmid: 1831552].
1295 Adamson GD, Nelson HP. Surgical treatment of endometriosis. Obstet Gynecol Clin North Am. 1997;24(2):375-409. X-1, X-2, X-3, X-4. [pmid: 9163773].
1296 Jamieson DJ, Steege JF. The prevalence of dysmenorrhea, dyspareunia, pelvic pain, and irritable bowel syndrome in primary care practices. Obstet Gynecol. 1996;87(1):55-8. X-2, X-3, X-4. [pmid: 8532266].
1297 Barbieri RL. Primary gonadotropin-releasing hormone agonist therapy for suspected endometriosis: a nonsurgical approach to the diagnosis and treatment of chronic pelvic pain. Am J Manag Care. 1997;3(2):285-90. X-1, X-2, X-3, X-4, X-5. [pmid: 10169263].
1298 Nafarelin for endometriosis: a large-scale, danazol-controlled trial of efficacy and safety, with 1-year follow-up. The Nafarelin European Endometriosis Trial Group (NEET). Fertil Steril. 1992;57(3):514-22. X-2, X-3. [pmid: 1531464].
1299 Wright S, et al. Short-term Lupron or danazol therapy for pelvic endometriosis. Fertil Steril. 1995;63(3):504-7. X-3. [pmid: 7851578].
1300 Adamson GD, et al. Therapeutic efficacy and bone mineral density response during and following a three-month re-treatment of endometriosis with nafarelin (Synarel). Am J Obstet Gynecol. 1997;177(6):1413-8. X-3. [pmid: 9423744].
1301 Eldred JM, Haynes PJ, Thomas EJ. A randomized double blind placebo controlled trial of the effects on bone metabolism of the combination of nafarelin acetate and norethisterone. Clin Endocrinol (Oxf). 1992;37(4):354-9. X-2, X-3, X-4, X-5. [pmid: 1483292].
1302 Perry CP. Peripheral neuropathies causing chronic pelvic pain. J Am Assoc Gynecol Laparosc. 2000;7(2):281-7. X-1, X-2, X-3. [pmid: 10806280].
1303 Fedele L, et al. Use of a levonorgestrel-releasing intrauterine device in the treatment of rectovaginal endometriosis. Fertil Steril. 2001;75(3):485-8. X-3. [pmid: 11239528].
1304 Lockhat FB, Emembolu JO, Konje JC. The evaluation of the effectiveness of an intrauterine-administered progestogen (levonorgestrel) in the symptomatic treatment of endometriosis and in the staging of the disease. Hum Reprod. 2004;19(1):179-84. X-3. [pmid: 14688179].
1305 Lockhat FB, Emembolu JO, Konje JC. The efficacy, side-effects and continuation rates in women with symptomatic endometriosis undergoing treatment with an intra-uterine administered progestogen (levonorgestrel): a 3 year follow-up. Hum Reprod. 2005;20(3):789-93. X-3. [pmid: 15608040].
1306 Fall M, et al. EAU guidelines on chronic pelvic pain. Eur Urol. 2010;57(1):35-48. X-1, X-2, X-3. [pmid: 19733958].
1307 Selak V, et al. Danazol for pelvic pain associated with endometriosis. Cochrane Database Syst Rev. 2007;(4):CD000068. X-1. [pmid: 17943735].
1308 Bogart LM, Berry SH, Clemens JQ. Symptoms of interstitial cystitis, painful bladder syndrome and similar diseases in women: a systematic review. J Urol. 2007;177(2):450-6. X-1, X-2, X-3, X-4. [pmid: 17222607].
1309 Parsons CL, et al. The prevalence of interstitial cystitis in gynecologic patients with pelvic pain, as detected by intravesical potassium sensitivity. Am J Obstet Gynecol. 2002;187(5):1395-400. X-3. [pmid: 12439537].
1310 Venbrux AC, Lambert DL. Embolization of the ovarian veins as a treatment for patients with chronic pelvic pain caused by pelvic venous incompetence (pelvic congestion syndrome). Curr Opin Obstet Gynecol. 1999;11(4):395-9. X-1, X-2, X-3. [pmid: 10498026].
1311 Soysal S, et al. The effects of post-surgical administration of goserelin plus anastrozole compared to goserelin alone in patients with severe endometriosis: a prospective randomized trial. Hum Reprod. 2004;19(1):160-7. X-2, X-3. [pmid: 14688176].
1312 Takayama K, et al. Treatment of severe postmenopausal endometriosis with an aromatase inhibitor. Fertil Steril. 1998;69(4):709-13. X-3. [pmid: 9548162].
1313 Whitehead WE, Palsson O, Jones KR. Systematic review of the comorbidity of irritable bowel syndrome with other disorders: what are the causes and implications?. Gastroenterology. 2002;122(4):1140-56. X-1, X-2, X-3, X-4. [pmid: 11910364].
1314 Abbott J, et al. Laparoscopic excision of endometriosis: a randomized, placebo-controlled trial. Fertil Steril. 2004;82(4):878-84. X-3. [pmid: 15482763].
1315 Gunter J. Chronic pelvic pain: an integrated approach to diagnosis and treatment. Obstet Gynecol Surv. 2003;58(9):615-23. X-1, X-2, X-3. [pmid: 12972837].
1316 Audebert A, et al. Pre or post-operative medical treatment with nafarelin in stage III-IV endometriosis: a French multicenter study. Eur J Obstet Gynecol Reprod Biol. 1998;79(2):145-8. X-2, X-3. [pmid: 9720832].
1317 Sutton CJ, et al. Follow-up report on a randomized controlled trial of laser laparoscopy in the treatment of pelvic pain associated with minimal to moderate endometriosis. Fertil Steril. 1997;68(6):1070-4. X-2, X-3. [pmid: 9418699].
1318 Bromham DR, et al. Updating the clinical experience in endometriosis--the European perspective. Br J Obstet Gynaecol. Suppl 12. 1995;102:12-6. X-2, X-3, X-4, X-5. [pmid: 7577849].
1319 Telimaa S, et al. Placebo-controlled comparison of hormonal and biochemical effects of danazol and high-dose medroxyprogesterone acetate. Eur J Obstet Gynecol Reprod Biol. 1990;36(1-2):97-105. X-2, X-3, X-4, X-5. [pmid: 2142109].
1320 Koninckx PR, et al. Anti-TNF-alpha treatment for deep endometriosis-associated pain: a randomized placebo-controlled trial. Hum Reprod. 2008;23(9):2017-23. X-3. [pmid: 18556683].
1321 Balasch J, et al. Pentoxifylline versus placebo in the treatment of infertility associated with minimal or mild endometriosis: a pilot randomized clinical trial. Hum Reprod. 1997;12(9):2046-50. X-2, X-3, X-4, X-5. [pmid: 9363727].
1322 Kamencic H, Thiel JA. Pentoxifylline after conservative surgery for endometriosis: a randomized, controlled trial. J Minim Invasive Gynecol. 2008;15(1):62-6. X-3. [pmid: 18262146].
1323 Neelakantan D, et al. Quality of life instruments in studies of chronic pelvic pain: a systematic review. J Obstet Gynaecol. 2004;24(8):851-8. X-1, X-2, X-3, X-4. [pmid: 16147635].
1324 Porpora MG, Gomel V. The role of laparoscopy in the management of pelvic pain in women of reproductive age. Fertil Steril. 1997;68(5):765-79. X-1, X-2, X-3. [pmid: 9389799].
1325 Bromham DR, et al. A multicentre comparative study of gestrinone and danazol in the treatment of endometriosis. Journal of Obstetrics & Gynaecology. 1995;15(3):188-194. X-3.
1326 Kjerulff KH, et al. Patient satisfaction with results of hysterectomy. Am J Obstet Gynecol. 2000;183(6):1440-7. X-2, X-3, X-4, X-5. [pmid: 11120508].
1327 Kjerulff KH, et al. Effectiveness of hysterectomy. Obstet Gynecol. 2000;95(3):319-26. X-2, X-3, X-4, X-5. [pmid: 10711536].
1328 Langenberg P, Kjerulff KH, Stolley PD. Hormone replacement and menopausal symptoms following hysterectomy. Am J Epidemiol. 1997;146(10):870-80. X-2, X-3, X-4, X-5. [pmid: 9384207].
1329 Rhodes JC, et al. Hysterectomy and sexual functioning. JAMA. 1999;282(20):1934-41. X-2, X-3, X-4, X-5. [pmid: 10580459].
1330 Gallicchio L, Harvey LA, Kjerulff KH. Fear of cancer among women undergoing hysterectomy for benign conditions. Psychosom Med. 2005;67(3):420-4. X-2, X-3, X-4, X-5. [pmid: 15911905].
1331 Handa VL, et al. Sexual function among women with urinary incontinence and pelvic organ prolapse. Am J Obstet Gynecol. 2004;191(3):751-6. X-2, X-3, X-4, X-5. [pmid: 15467535].
1332 Kuppermann M, et al. Effect of hysterectomy vs medical treatment on health-related quality of life and sexual functioning: the medicine or surgery (Ms) randomized trial. JAMA. 2004;291(12):1447-55. X-2, X-3, X-4, X-5. [pmid: 15039411].
1333 Daniels JP, Khan KS. Chronic pelvic pain in women. BMJ. 2010;341:c4834. X-1, X-2, X-3, X-4, X-5. [pmid: 20923840].
1334 Pontari MA, et al. Pregabalin for the treatment of men with chronic prostatitis/chronic pelvic pain syndrome: a randomized controlled trial. Arch Intern Med. 2010;170(17):1586-93. X-2, X-3, X-4. [pmid: 20876412].
1335 Bonnema RA, McNamara MC, Spencer AL. Contraception choices in women with underlying medical conditions. Am Fam Physician. 2010;82(6):621-8. X-1, X-2, X-3, X-4, X-5. [pmid: 20842989].
1336 Ngo C, et al. Protein kinase inhibitors can control the progression of endometriosis in vitro and in vivo. J Pathol. 2010;222(2):148-57. X-2, X-3, X-4. [pmid: 20821752].
1337 Stahl C, et al. MRI features of gastrocnemius musculotendinopathy in herding dogs. Vet Radiol Ultrasound. 2010;51(4):380-5. X-2, X-3, X-4. [pmid: 20806868].
1338 Thumbikat P, et al. Prostate secretions from men with chronic pelvic pain syndrome inhibit proinflammatory mediators. J Urol. 2010;184(4):1536-42. X-2, X-3, X-4. [pmid: 20723928].
1339 Poleshuck EL, et al. Interpersonal psychotherapy for women with comorbid depression and chronic pain. J Nerv Ment Dis. 2010;198(8):597-600. X-3. [pmid: 20699727].
1340 Alderete J, et al. Morbidity and functional status of patients with pelvic neurogenic tumors after wide excision. Clin Orthop Relat Res. 2010;468(11):2948-53. X-2, X-3, X-4. [pmid: 20668971].
1341 Soper DE. Pelvic inflammatory disease. Obstet Gynecol. 2010;116(2 Pt 1):419-28. X-1, X-2, X-3, X-4. [pmid: 20664404].
1342 Kovoor E, et al. Endometriosis of bladder: outcomes after laparoscopic surgery. J Minim Invasive Gynecol. 2010;17(5):600-4. X-2, X-3, X-4. [pmid: 20656568].
1343 Rigaud J, et al. Functional results after tape removal for chronic pelvic pain following tension-free vaginal tape or transobturator tape. J Urol. 2010;184(2):610-5. X-3. [pmid: 20639025].
1344 Akiyama T, et al. The non-vascularised fibular graft: a simple and successful method of reconstruction of the pelvic ring after internal hemipelvectomy. J Bone Joint Surg Br. 2010;92(7):999-1005. X-2, X-3, X-4. [pmid: 20595122].
1345 Umbreit EC, et al. Multifactorial, site-specific recurrence model after radical cystectomy for urothelial carcinoma. Cancer. 2010;116(14):3399-407. X-2, X-3, X-4. [pmid: 20564121].
1346 Watanabe S, et al. Influence of trunk muscle co-contraction on spinal curvature during sitting cross-legged. Electromyogr Clin Neurophysiol. 2010;50(3-4):187-92. X-2, X-3, X-4. [pmid: 20552952].
1347 Canavese F, et al. Varus derotation osteotomy for the treatment of hip subluxation and dislocation in GMFCS level III to V patients with unilateral hip involvement. Follow-up at skeletal maturity. J Pediatr Orthop. 2010;30(4):357-64. X-2, X-3, X-4. [pmid: 20502236].
1348 Ouzounova-Raykova V, Ouzounova I, Mitov IG. May Chlamydia trachomatis be an aetiological agent of chronic prostatic infection?. Andrologia. 2010;42(3):176-81. X-2, X-3, X-4. [pmid: 20500746].
1349 Parker J, et al. Advancements in the management of urologic chronic pelvic pain: what is new and what do we know?. Curr Urol Rep. 2010;11(4):286-91. X-1, X-2, X-3, X-4. [pmid: 20449695].
1350 McIntyre M, Fisch H. Ejaculatory duct dysfunction and lower urinary tract symptoms: chronic prostatitis. Curr Urol Rep. 2010;11(4):271-5. X-1, X-2, X-3, X-4. [pmid: 20440584].
1351 Xue-Song L, et al. Surgical excision of extensive sacrococcygeal chordomas assisted by occlusion of the abdominal aorta. J Neurosurg Spine. 2010;12(5):490-6. X-2, X-3, X-4. [pmid: 20433296].
1352 Chung MK, Butrick CW, Chung CW. The overlap of interstitial cystitis/painful bladder syndrome and overactive bladder. JSLS. 2010;14(1):83-90. X-2, X-3, X-4, X-5. [pmid: 20412643].
1353 Morgia G, et al. Treatment of chronic prostatitis/chronic pelvic pain syndrome category IIIA with Serenoa repens plus selenium and lycopene (Profluss) versus S. repens alone: an Italian randomized multicenter-controlled study. Urol Int. 2010;84(4):400-6. X-2, X-3, X-4. [pmid: 20332612].
1354 Radosa MP, et al. Coagulation versus excision of primary superficial endometriosis: a 2-year follow-up. Eur J Obstet Gynecol Reprod Biol. 2010;150(2):195-8. X-2, X-3, X-4, X-5. [pmid: 20303642].
1355 Sharma JB, et al. Increased complication rates associated with laparoscopic surgery among patients with genital tuberculosis. Int J Gynaecol Obstet. 2010;109(3):242-4. X-4. [pmid: 20206350].
1356 Takahashi S, et al. Tension-free vaginal mesh procedure for pelvic organ prolapse: a single-center experience of 310 cases with 1-year follow up. Int J Urol. 2010;17(4):353-8. X-3, X-4. [pmid: 20202001].
1357 Zhu L, et al. Epidemiological study of urge urinary incontinence and risk factors in China. Int Urogynecol J Pelvic Floor Dysfunct. 2010;21(5):589-93. X-2, X-3, X-4.
1358 Indraccolo U, Barbieri F. Effect of palmitoylethanolamide-polydatin combination on chronic pelvic pain associated with endometriosis: preliminary observations. Eur J Obstet Gynecol Reprod Biol. 2010;150(1):76-9. X-3. [pmid: 20176435].
1359 Karatas OF, et al. Helicobacter pylori seroprevalence in patients with chronic prostatitis: a pilot study. Scand J Urol Nephrol. 2010;44(2):91-4. X-2, X-3, X-4. [pmid: 20163196].
1360 Castori M, et al. Natural history and manifestations of the hypermobility type Ehlers-Danlos syndrome: a pilot study on 21 patients. Am J Med Genet A. 2010;152A(3):556-64. X-2, X-3, X-4. [pmid: 20140961].
1361 Tugcu V, et al. Effectiveness of acupuncture in patients with category IIIB chronic pelvic pain syndrome: a report of 97 patients. Pain Med. 2010;11(4):518-23. X-2, X-3, X-4. [pmid: 20113410].
1362 Gerbershagen HJ, et al. Chronic pain and disability after pelvic and acetabular fractures--assessment with the Mainz Pain Staging System. J Trauma. 2010;69(1):128-36. X-3, X-4, X-5. [pmid: 20093984].
1363 Velasco I, et al. Interleukin-6 and other soluble factors in peritoneal fluid and endometriomas and their relation to pain and aromatase expression. J Reprod Immunol. 2010;84(2):199-205. X-4. [pmid: 20074813].
1364 Ruka W, et al. The megavoltage radiation therapy in treatment of patients with advanced or difficult giant cell tumors of bone. Int J Radiat Oncol Biol Phys. 2010;78(2):494-8. X-2, X-3, X-4. [pmid: 20004531].
1365 Montenegro ML, et al. Importance of pelvic muscle tenderness evaluation in women with chronic pelvic pain. Pain Med. 2010;11(2):224-8. X-2, X-3. [pmid: 20002593].
1366 Egol KA, Singh JR, Nwosu U. Functional outcome in patients treated for chronic posttraumatic osteomyelitis. Bull NYU Hosp Jt Dis. 2009;67(4):313-7. X-2, X-3, X-4. [pmid: 20001930].
1367 Guo W, et al. Surgical treatment of pelvic chondrosarcoma involving periacetabulum. J Surg Oncol. 2010;101(2):160-5. X-2, X-3, X-4. [pmid: 19960486].
1368 Di Schino M, et al. Anterior dislocation of a total hip replacement. Radiographic and CT-scan assessment. Behavior following conservative management. Orthop Traumatol Surg Res. 2009;95(8):573-8. X-2, X-3, X-4. [pmid: 19945930].
1369 Janis JE, et al. A 25-year experience with hemicorporectomy for terminal pelvic osteomyelitis. Plast Reconstr Surg. 2009;124(4):1165-76. X-2, X-3, X-4. [pmid: 19935300].
1370 Balke M, et al. Treatment and outcome of giant cell tumors of the pelvis. Acta Orthop. 2009;80(5):590-6. X-2, X-3, X-4. [pmid: 19916695].
1371 Li CZ, et al. Feasibility of focused ultrasound therapy for recurrent cervicitis with high-risk human papillomavirus infection. Ultrasound Obstet Gynecol. 2009;34(5):590-4. X-2, X-3, X-4. [pmid: 19852044].
1372 Deloin X, et al. Pelvic chondrosarcomas: surgical treatment options. Orthop Traumatol Surg Res. 2009;95(6):393-401. X-2, X-3, X-4. [pmid: 19801212].
1373 Kishi K, et al. Critical organ preservation in reirradiation brachytherapy by injectable spacer. Int J Radiat Oncol Biol Phys. 2009;75(2):587-94. X-2, X-3, X-4. [pmid: 19735885].
1374 Renner SP, et al. Preoperative pain and recurrence risk in patients with peritoneal endometriosis. Gynecol Endocrinol. 2010;26(3):230-5. X-2, X-3, X-4, X-5. [pmid: 19718567].
1375 Kotnis NA, et al. Magnetic resonance imaging appearances following hindquarter amputation for pelvic musculoskeletal malignancy. Skeletal Radiol. 2009;38(12):1137-46. X-2, X-3, X-4. [pmid: 19697024].
1376 Farid YR. Decancellation sacral osteotomy in iliosacral tumor resection: a technique for precise sacral margins. Clin Orthop Relat Res. 2010;468(5):1362-72. X-2, X-3, X-4. [pmid: 19690933].
1377 Tennant S, et al. CT staging of loco-regional breast cancer recurrence. A worthwhile practice?. Clin Radiol. 2009;64(9):885-90. X-2, X-3, X-4. [pmid: 19664478].
1378 Lacativa PG, et al. Prevalence of radiological findings among cases of severe secondary hyperparathyroidism. Sao Paulo Med J. 2009;127(2):71-7. X-2, X-3, X-4. [pmid: 19597681].
1379 Beheshti M, et al. The use of F-18 choline PET in the assessment of bone metastases in prostate cancer: correlation with morphological changes on CT. Mol Imaging Biol. 2010;12(1):98-107. X-2, X-3, X-4. [pmid: 19588206].
1380 Wang CB, et al. Cesarean scar defect: correlation between Cesarean section number, defect size, clinical symptoms and uterine position. Ultrasound Obstet Gynecol. 2009;34(1):85-9. X-2, X-3, X-4, X-5. [pmid: 19565535].
1381 Bulletti C, et al. Vaginal parturition decreases recurrence of endometriosis. Fertil Steril. 2010;94(3):850-5. X-2, X-3, X-4, X-5. [pmid: 19524893].
1382 Seracchioli R, et al. Conservative laparoscopic management of urinary tract endometriosis (UTE): surgical outcome and long-term follow-up. Fertil Steril. 2010;94(3):856-61. X-2, X-3, X-4, X-5. [pmid: 19481740].
1383 Goldfinger C, et al. A prospective study of pelvic floor physical therapy: pain and psychosexual outcomes in provoked vestibulodynia. J Sex Med. 2009;6(7):1955-68. X-3. [pmid: 19453890].
1384 Manero MG, Alcazar JL. Interleukin-8 serum levels do not correlate with pelvic pain in patients with ovarian endometriomas. Fertil Steril. 2010;94(2):450-2. X-4. [pmid: 19423093].
1385 Romao AP, et al. High levels of anxiety and depression have a negative effect on quality of life of women with chronic pelvic pain. Int J Clin Pract. 2009;63(5):707-11. X-2, X-3. [pmid: 19392920].
1386 Lackman RD, et al. Internal hemipelvectomy for pelvic sarcomas using a T-incision surgical approach. Clin Orthop Relat Res. 2009;467(10):2677-84. X-2, X-3, X-4. [pmid: 19381740].
1387 Van Kleunen JP, et al. Acetabular revisions using trabecular metal cups and augments. J Arthroplasty. 2009;24(6 Suppl):64-8. X-2, X-3, X-4. [pmid: 19339154].
1388 Beheshti M, et al. The use of F-18 choline PET in the assessment of bone metastases in prostate cancer: correlation with morphological changes on CT. Mol Imaging Biol. 2009;11(6):446-54. X-2, X-3, X-4. [pmid: 19326171].
1389 Timmers MS, et al. Negative pressure wound treatment with polyvinyl alcohol foam and polyhexanide antiseptic solution instillation in posttraumatic osteomyelitis. Wound Repair Regen. 2009;17(2):278-86. X-2, X-3, X-4. [pmid: 19320897].
1390 Pollanen R, et al. Microbial antigens mediate HLA-B27 diseases via TLRs. J Autoimmun. 2009;32(3-4):172-7. X-2, X-3, X-4. [pmid: 19299108].
1391 Krieg AH, et al. Extracorporeal irradiation for pelvic reconstruction in Ewing's sarcoma. J Bone Joint Surg Br. 2009;91(3):395-400. X-2, X-3, X-4. [pmid: 19258619].
1392 Krakow D, et al. Mutations in the gene encoding the calcium-permeable ion channel TRPV4 produce spondylometaphyseal dysplasia, Kozlowski type and metatropic dysplasia. Am J Hum Genet. 2009;84(3):307-15. X-2, X-3, X-4. [pmid: 19232556].
1393 Donati D, et al. Management of pelvic giant cell tumours involving the acetabular bone. Acta Orthop Belg. 2008;74(6):773-8. X-2, X-3, X-4. [pmid: 19205324].
1394 Werner CM, et al. Prevalence of acetabular dome retroversion in a mixed race adult trauma patient population. Acta Orthop Belg. 2008;74(6):766-72. X-2, X-3, X-4. [pmid: 19205323].
1395 Niibe Y, et al. Value of high-dose radiation therapy for isolated osseous metastasis in breast cancer in terms of oligo-recurrence. Anticancer Res. 2008;28(6B):3929-31. X-2, X-3, X-4. [pmid: 19192651].
1396 Wagner TD, et al. Combination short-course preoperative irradiation, surgical resection, and reduced-field high-dose postoperative irradiation in the treatment of tumors involving the bone. Int J Radiat Oncol Biol Phys. 2009;73(1):259-66. X-2, X-3, X-4. [pmid: 19100921].
1397 Franklyn-Miller A, Falvey E, McCrory P. The gluteal triangle: a clinical patho-anatomical approach to the diagnosis of gluteal pain in athletes. Br J Sports Med. 2009;43(6):460-6. X-1, X-2, X-3, X-4. [pmid: 19019911].
1398 Ataergin S, et al. Long-lasting multiagent chemotherapy in adult high-risk Ewing's sarcoma of bone. Med Oncol. 2009;26(3):276-86. X-2, X-3, X-4. [pmid: 18989798].
1399 Fuchs B, et al. Osteosarcoma of the pelvis: outcome analysis of surgical treatment. Clin Orthop Relat Res. 2009;467(2):510-8. X-2, X-3, X-4. [pmid: 18855090].
1400 Streitburger A, et al. Grade I chondrosarcoma of bone: the Munster experience. J Cancer Res Clin Oncol. 2009;135(4):543-50. X-2, X-3, X-4. [pmid: 18855011].
1401 Restrepo C, et al. Isolated polyethylene exchange versus acetabular revision for polyethylene wear. Clin Orthop Relat Res. 2009;467(1):194-8. X-2, X-3, X-4. [pmid: 18846409].
1402 Abed R, Younge D. Surgical management of very large musculoskeletal sarcomas. Ann N Y Acad Sci. 2008;1138:77-83. X-1, X-2, X-3, X-4, X-5. [pmid: 18837887].
1403 Park KB, et al. Surgical treatment of calcaneal deformity in a select group of patients with myelomeningocele. J Bone Joint Surg Am. 2008;90(10):2149-59. X-2, X-3, X-4. [pmid: 18829913].
1404 Garras DN, Carothers JT, Olson SA. Single-leg-stance (flamingo) radiographs to assess pelvic instability: how much motion is normal?. J Bone Joint Surg Am. 2008;90(10):2114-8. X-2, X-3, X-4. [pmid: 18829908].
1405 Neckel ND, et al. Abnormal joint torque patterns exhibited by chronic stroke subjects while walking with a prescribed physiological gait pattern. J Neuroeng Rehabil. 2008;5:19. X-2, X-3, X-4. [pmid: 18761735].
1406 Jaiswal PK, et al. Peri-acetabular resection and endoprosthetic reconstruction for tumours of the acetabulum. J Bone Joint Surg Br. 2008;90(9):1222-7. X-2, X-3, X-4. [pmid: 18757964].
1407 Rodriguez-Garcia M, et al. Vascular calcifications, vertebral fractures and mortality in haemodialysis patients. Nephrol Dial Transplant. 2009;24(1):239-46. X-2, X-3, X-4. [pmid: 18725376].
1408 Trigui M, et al. Coxa vara in chondrodysplasia: prognosis study of 35 hips in 19 children. J Pediatr Orthop. 2008;28(6):599-606. X-2, X-3, X-4. [pmid: 18724194].
1409 Hanna SA, et al. Sacral chordoma: can local recurrence after sacrectomy be predicted?. Clin Orthop Relat Res. 2008;466(9):2217-23. X-2, X-3, X-4. [pmid: 18584264].
1410 Jager M, et al. Hyperthermia associated osteonecrosis in young patients with pelvic malignancies. Anticancer Agents Med Chem. 2008;8(5):571-5. X-2, X-3, X-4. [pmid: 18537538].
1411 Flecher X, Sporer S, Paprosky W. Management of severe bone loss in acetabular revision using a trabecular metal shell. J Arthroplasty. 2008;23(7):949-55. X-2, X-3, X-4. [pmid: 18534494].
1412 Jeys LM, et al. Endoprosthetic reconstruction for the treatment of musculoskeletal tumors of the appendicular skeleton and pelvis. J Bone Joint Surg Am. 2008;90(6):1265-71. X-2, X-3, X-4. [pmid: 18519320].
1413 Orban H, et al. Great omentum plasty--original method of treatment of the septic complications of hip and pelvis surgery. Chirurgia (Bucur). 2008;103(1):53-6. X-2, X-3, X-4. [pmid: 18459497].
1414 Willson JD, Binder-Macleod S, Davis IS. Lower extremity jumping mechanics of female athletes with and without patellofemoral pain before and after exertion. Am J Sports Med. 2008;36(8):1587-96. X-2, X-3, X-4. [pmid: 18448577].
1415 Dantonello TM, et al. Mesenchymal chondrosarcoma of soft tissues and bone in children, adolescents, and young adults: experiences of the CWS and COSS study groups. Cancer. 2008;112(11):2424-31. X-2, X-3, X-4. [pmid: 18438777].
1416 Dernis E, et al. Recurrence of spondylarthropathy among first-degree relatives of patients: a systematic cross-sectional study. Ann Rheum Dis. 2009;68(4):502-7. X-2, X-3, X-4. [pmid: 18413442].
1417 Perlmutter MA, Lepor H. Prostate-specific antigen doubling time is a reliable predictor of imageable metastases in men with biochemical recurrence after radical retropubic prostatectomy. Urology. 2008;71(3):501-5. X-2, X-3, X-4. [pmid: 18342197].
1418 Ziran BH, Smith WR, Rao N. Hemipelvic amputations for recalcitrant pelvic osteomyelitis. Injury. 2008;39(4):411-8. X-2, X-3, X-4. [pmid: 18321513].
1419 Peersman B, et al. Ewing's sarcoma: imaging features. JBR-BTR. 2007;90(5):368-76. X-2, X-3, X-4. [pmid: 18085191].
1420 Hatef E, et al. Prevalence and nature of systemic involvement and stage at initial examination in patients with orbital and ocular adnexal lymphoma. Arch Ophthalmol. 2007;125(12):1663-7. X-2, X-3, X-4. [pmid: 18071119].
1421 Kim MJ, et al. Targeted percutaneous transforaminal endoscopic diskectomy in 295 patients: comparison with results of microscopic diskectomy. Surg Neurol. 2007;68(6):623-31. X-2, X-3, X-4. [pmid: 18053857].
1422 Laus M, et al. Osteoid osteoma of the cervical spine: surgical treatment or percutaneous radiofrequency coagulation?. Eur Spine J. 2007;16(12):2078-82. X-2, X-3, X-4. [pmid: 17874147].
1423 Grimer RJ, et al. Dedifferentiated chondrosarcoma: prognostic factors and outcome from a European group. Eur J Cancer. 2007;43(14):2060-5. X-2, X-3, X-4. [pmid: 17720491].
1424 Yonemori K, et al. Prediction of response and prognostic factors for Ewing family of tumors in a low incidence population. J Cancer Res Clin Oncol. 2008;134(3):389-95. X-2, X-3, X-4. [pmid: 17687565].
1425 Mitchell PD, et al. The value of MRI undertaken immediately after reduction of the hip as a predictor of long-term acetabular dysplasia. J Bone Joint Surg Br. 2007;89(7):948-52. X-2, X-3, X-4. [pmid: 17673592].
1426 Guichelaar MM, et al. Fractures and avascular necrosis before and after orthotopic liver transplantation: long-term follow-up and predictive factors. Hepatology. 2007;46(4):1198-207. X-2, X-3, X-4. [pmid: 17654700].
1427 Correa GI, et al. Proximal amputation of inferior extremity secondary to recurrent pressure ulcers in patients with spinal cord injuries. Spinal Cord. 2008;46(2):135-9. X-2, X-3, X-4. [pmid: 17607312].
1428 Kirkpatrick AW, et al. The secondary and recurrent abdominal compartment syndrome. Acta Clin Belg Suppl. 2007;(1):60-5. X-2, X-3, X-4. [pmid: 17469702].
1429 Kinsella S, Moran K. Gait pattern categorization of stroke participants with equinus deformity of the foot. Gait Posture. 2008;27(1):144-51. X-2, X-3, X-4. [pmid: 17467274].
1430 Guo W, et al. Reconstruction with modular hemipelvic prostheses for periacetabular tumor. Clin Orthop Relat Res. 2007;461:180-8. X-2, X-3, X-4. [pmid: 17452921].
1431 Yasko AW, et al. Disease- and recurrence-free survival after surgical resection of solitary bone metastases of the pelvis. Clin Orthop Relat Res. 2007;459:128-32. X-2, X-3, X-4. [pmid: 17452920].
1432 Normand AN, et al. Curettage of biopsy-diagnosed grade 1 periacetabular chondrosarcoma. Clin Orthop Relat Res. 2007;459:146-9. X-2, X-3, X-4. [pmid: 17452919].
1433 Kattapuram TM, et al. Imaging of pseudoneoplastic masses associated with allografts. Skeletal Radiol. 2007;36(8):747-53. X-2, X-3, X-4. [pmid: 17415562].
1434 Delloye C, et al. Pelvic reconstruction with a structural pelvic allograft after resection of a malignant bone tumor. J Bone Joint Surg Am. 2007;89(3):579-87. X-2, X-3, X-4. [pmid: 17332107].
1435 Weber U, et al. Whole body MR imaging in ankylosing spondylitis: a descriptive pilot study in patients with suspected early and active confirmed ankylosing spondylitis. BMC Musculoskelet Disord. 2007;8:20. X-2, X-3, X-4. [pmid: 17326845].
1436 Kunduracioglu B, et al. Magnetic resonance findings of osteitis pubis. J Magn Reson Imaging. 2007;25(3):535-9. X-2, X-3, X-4. [pmid: 17326088].
1437 Hamouda WE, Roshdy W, Teema M. Single versus conventional fractionated radiotherapy in the palliation of painful bone metastases. Gulf J Oncolog. 2007;1(1):35-41. X-2, X-3, X-4. [pmid: 20084712].
1438 Lin PP, et al. Chemotherapy response is an important predictor of local recurrence in Ewing sarcoma. Cancer. 2007;109(3):603-11. X-2, X-3, X-4. [pmid: 17177205].
1439 Sale GE, Deeg HJ, Porter BA. Regression of myelofibrosis and osteosclerosis following hematopoietic cell transplantation assessed by magnetic resonance imaging and histologic grading. Biol Blood Marrow Transplant. 2006;12(12):1285-94. X-2, X-3, X-4. [pmid: 17162210].
1440 Bhadada S, et al. Does Paget's disease exist in India?: A series of 21 patients. J Assoc Physicians India. 2006;54:530-4. X-2, X-3, X-4. [pmid: 17089900].
1441 Timmermann B, et al. Spot-scanning proton therapy for malignant soft tissue tumors in childhood: First experiences at the Paul Scherrer Institute. Int J Radiat Oncol Biol Phys. 2007;67(2):497-504. X-2, X-3, X-4. [pmid: 17084557].
1442 Akasu T, et al. Abdominal sacral resection for posterior pelvic recurrence of rectal carcinoma: analyses of prognostic factors and recurrence patterns. Ann Surg Oncol. 2007;14(1):74-83. X-2, X-3, X-4. [pmid: 17061173].
1443 Mermer MJ, et al. Comprehensive analysis of cantilever, translational, and modular corrective techniques in adults with scoliosis treated with surgery to the sacropelvis. J Spinal Disord Tech. 2006;19(7):513-22. X-2, X-3, X-4. [pmid: 17021416].
1444 Balzer S, et al. Avascular osteonecrosis after hyperthermia in children and adolescents with pelvic malignancies: a retrospective analysis of potential risk factors. Int J Hyperthermia. 2006;22(6):451-61. X-2, X-3, X-4. [pmid: 16971366].
1445 Yock TI, et al. Local control in pelvic Ewing sarcoma: analysis from INT-0091--a report from the Children's Oncology Group. J Clin Oncol. 2006;24(24):3838-43. X-2, X-3, X-4. [pmid: 16921035].
1446 Kitagawa Y, Ek ET, Choong PF. Pelvic reconstruction using saddle prosthesis following limb salvage operation for periacetabular tumour. J Orthop Surg (Hong Kong). 2006;14(2):155-62. X-2, X-3, X-4. [pmid: 16914780].
1447 McCrory JL, et al. The effect of a single treatment of the Protonics system on lower extremity kinematics during gait and the lateral step up exercise. Gait Posture. 2007;25(4):544-8. X-2, X-3, X-4. [pmid: 16887352].
1448 Vallamshetla VR, Mughal E, O'Hara JN. Congenital dislocation of the hip. A re-appraisal of the upper age limit for treatment. J Bone Joint Surg Br. 2006;88(8):1076-81. X-2, X-3, X-4. [pmid: 16877609].
1449 Knox K, et al. Immediate reconstruction of oncologic hemipelvectomy defects. Ann Plast Surg. 2006;57(2):184-9. X-2, X-3, X-4. [pmid: 16862000].
1450 Sobhgol SS, Alizadeli Charndabee SM. Rate and related factors of dyspareunia in reproductive age women: a cross-sectional study. Int J Impot Res. 2007;19(1):88-94. X-2, X-3, X-4. [pmid: 16791280].
1451 Court C, et al. Surgical excision of bone sarcomas involving the sacroiliac joint. Clin Orthop Relat Res. 2006;451:189-94. X-2, X-3, X-4. [pmid: 16770289].
1452 Voorham-van der Zalm PJ, et al. Effects of magnetic stimulation in the treatment of pelvic floor dysfunction. BJU Int. 2006;97(5):1035-8. X-2, X-3, X-4. [pmid: 16643487].
1453 Nishida J, et al. Vascularized iliac bone graft for iliosacral bone defect after tumor excision. Clin Orthop Relat Res. 2006;447:145-51. X-2, X-3, X-4. [pmid: 16505711].
1454 Oh CW, et al. Coxa vara: a novel measurement technique in skeletal dysplasias. Clin Orthop Relat Res. 2006;447:125-31. X-2, X-3, X-4. [pmid: 16505708].
1455 Theodorou SJ, et al. Magnetic resonance imaging of para-acetabular insufficiency fractures in patients with malignancy. Clin Radiol. 2006;61(2):181-90. X-2, X-3, X-4. [pmid: 16439224].
1456 Engin G. Cervical cancer: MR imaging findings before, during, and after radiation therapy. Eur Radiol. 2006;16(2):313-24. X-2, X-3, X-4. [pmid: 16425027].
1457 Paulino AC, Nguyen TX, Mai WY. An analysis of primary site control and late effects according to local control modality in non-metastatic Ewing sarcoma. Pediatr Blood Cancer. 2007;48(4):423-9. X-2, X-3, X-4. [pmid: 16421909].
1458 Cedidi CC, Felmerer G, Berger A. Management of defects in the groin, thigh, and pelvic region with modified contralateral TRAM/VRAM flaps. Eur J Med Res. 2005;10(12):515-20. X-2. [pmid: 16356866].
1459 Kato H, et al. Comparison between whole-body positron emission tomography and bone scintigraphy in evaluating bony metastases of esophageal carcinomas. Anticancer Res. 2005;25(6C):4439-44. X-2, X-3, X-4. [pmid: 16334123].
1460 Donati D, et al. Surgical treatment and outcome of conventional pelvic chondrosarcoma. J Bone Joint Surg Br. 2005;87(11):1527-30. X-2, X-3, X-4. [pmid: 16260673].
1461 Lersundi A, et al. Chondromyxoid fibroma: a rarely encountered and puzzling tumor. Clin Orthop Relat Res. 2005;439:171-5. X-2, X-3, X-4. [pmid: 16205156].
1462 Docquier PL, Delloye C. Treatment of aneurysmal bone cysts by introduction of demineralized bone and autogenous bone marrow. J Bone Joint Surg Am. 2005;87(10):2253-8. X-2, X-3, X-4. [pmid: 16203891].
1463 Beslikas TA, et al. Chronic osteomyelitis of the pelvis in children and adolescents. Acta Orthop Belg. 2005;71(4):405-9. X-2, X-3, X-4. [pmid: 16187445].
1464 Cremata E, et al. Manipulation under anesthesia: a report of four cases. J Manipulative Physiol Ther. 2005;28(7):526-33. X-3. [pmid: 16182028].
1465 Lin PP, et al. Treatment and prognosis of chondroblastoma. Clin Orthop Relat Res. 2005;438:103-9. X-2, X-3, X-4. [pmid: 16131877].
1466 Aljassir F, et al. Outcome after pelvic sarcoma resection reconstructed with saddle prosthesis. Clin Orthop Relat Res. 2005;438:36-41. X-2, X-3, X-4. [pmid: 16131867].
1467 Beadel GP, et al. Iliosacral resection for primary bone tumors: is pelvic reconstruction necessary?. Clin Orthop Relat Res. 2005;438:22-9. X-2, X-3, X-4. [pmid: 16131865].
1468 Yun AG, et al. Constrained acetabular liners: mechanisms of failure. J Arthroplasty. 2005;20(4):536-41. X-2, X-3, X-4. [pmid: 16124973].
1469 Matsuo T, et al. Clinical outcomes of 54 pelvic osteosarcomas registered by Japanese musculoskeletal oncology group. Oncology. 2005;68(4-6):375-81. X-2, X-3, X-4. [pmid: 16020966].
1470 Hayashi M, Tanaka G, Okutani T. Modified pluck method in en bloc nephroureterectomy with bladder cuff for upper urothelial cancer. Int J Urol. 2005;12(6):539-43. X-2, X-3, X-4. [pmid: 15985074].
1471 Faisham WI, et al. Osteosarcoma: the outcome of limb salvage surgery. Med J Malaysia. Suppl F. 2004;59:24-34. X-2, X-3, X-4. [pmid: 15941157].
1472 Vakili B, et al. Levator contraction strength and genital hiatus as risk factors for recurrent pelvic organ prolapse. Am J Obstet Gynecol. 2005;192(5):1592-8. X-2, X-3, X-4, X-5. [pmid: 15902163].
1473 Culligan PJ, et al. A randomized, double-blinded, sham-controlled trial of postpartum extracorporeal magnetic innervation to restore pelvic muscle strength in primiparous patients. Am J Obstet Gynecol. 2005;192(5):1578-82. X-2, X-3, X-4. [pmid: 15902161].
1474 Pant R, et al. Chondrosarcoma of the scapula: long-term oncologic outcome. Cancer. 2005;104(1):149-58. X-2, X-3, X-4. [pmid: 15895373].
1475 Parikh SN, Kreder HJ. Pelvic reconstruction for massive acetabular insufficiency. Clin Orthop Relat Res. 2005;(434):217-21. X-2, X-3, X-4. [pmid: 15864056].
1476 Traina F, et al. Structural allograft and primary press-fit cup for severe acetabular deficiency. A minimum 6-year follow-up study. Int Orthop. 2005;29(3):135-9. X-2, X-3, X-4. [pmid: 15809874].
1477 Bruns J, et al. Dedifferentiated chondrosarcoma--a fatal disease. J Cancer Res Clin Oncol. 2005;131(6):333-9. X-2, X-3, X-4. [pmid: 15785935].
1478 Francoeur RB. The relationship of cancer symptom clusters to depressive affect in the initial phase of palliative radiation. J Pain Symptom Manage. 2005;29(2):130-55. X-2, X-3, X-4. [pmid: 15733806].
1479 Vieillard MH, et al. Contribution of percutaneous biopsy to the definite diagnosis in patients with suspected bone tumor. Joint Bone Spine. 2005;72(1):53-60. X-2, X-3, X-4. [pmid: 15681249].
1480 DeLaney TF, et al. Radiotherapy for local control of osteosarcoma. Int J Radiat Oncol Biol Phys. 2005;61(2):492-8. X-2, X-3, X-4. [pmid: 15667972].
1481 Kutluk MT, et al. Treatment results and prognostic factors in Ewing sarcoma. Pediatr Hematol Oncol. 2004;21(7):597-610. X-2, X-3, X-4. [pmid: 15626016].
1482 Lee FY, et al. Diagnostic value and limitations of fluorine-18 fluorodeoxyglucose positron emission tomography for cartilaginous tumors of bone. J Bone Joint Surg Am. 2004;86-A(12):2677-85. X-2, X-3, X-4. [pmid: 15590853].
1483 Aydinli U, et al. Limb-sparing surgery for primary malignant tumours of the pelvis. Acta Orthop Belg. 2004;70(5):417-22. X-2, X-3, X-4. [pmid: 15587029].
1484 Juhl JH, Ippolito Cremin TM, Russell G. Prevalence of frontal plane pelvic postural asymmetry--part 1. J Am Osteopath Assoc. 2004;104(10):411-21. X-2, X-3, X-4. [pmid: 15537798].
1485 Adib N, et al. Isolated inflammatory coxitis associated with protrusio acetabuli: a new form of juvenile idiopathic arthritis. Rheumatology (Oxford). 2005;44(2):219-26. X-2, X-3, X-4. [pmid: 15494352].
1486 Sung MS, et al. Sacrococcygeal chordoma: MR imaging in 30 patients. Skeletal Radiol. 2005;34(2):87-94. X-2, X-3, X-4. [pmid: 15480648].
1487 Zeifang F, et al. Complications following operative treatment of primary malignant bone tumours in the pelvis. Eur J Surg Oncol. 2004;30(8):893-9. X-2, X-3, X-4. [pmid: 15336737].
1488 Jacobsen S, et al. The relationship of hip joint space to self reported hip pain. A survey of 4.151 subjects of the Copenhagen City Heart Study: the Osteoarthritis Substudy. Osteoarthritis Cartilage. 2004;12(9):692-7. X-2, X-3, X-4. [pmid: 15325634].
1489 Gedik GK, et al. Is corticosteroid coinjection necessary for radiosynoviorthesis of patients with hemophilia?. Clin Nucl Med. 2004;29(9):538-41. X-2, X-3, X-4. [pmid: 15311118].
1490 Citron JR, et al. Pathologic stage I-II endometrial carcinoma in the elderly: radiotherapy indications and outcome. Int J Radiat Oncol Biol Phys. 2004;59(5):1432-8. X-2, X-3, X-4. [pmid: 15275729].
1491 Urioste M, et al. Malignant degeneration of presacral teratoma in the Currarino anomaly. Am J Med Genet A. 2004;128A(3):299-304. X-2, X-3, X-4. [pmid: 15216552].
1492 Andresen KJ, et al. Imaging features of low-grade central osteosarcoma of the long bones and pelvis. Skeletal Radiol. 2004;33(7):373-9. X-2, X-3, X-4. [pmid: 15175837].
1493 Okotie OT, et al. Predictors of metastatic disease in men with biochemical failure following radical prostatectomy. J Urol. 2004;171(6 Pt 1):2260-4. X-2, X-3, X-4. [pmid: 15126798].
1494 Violante FS, et al. Associations of psychosocial and individual factors with three different categories of back disorder among nursing staff. J Occup Health. 2004;46(2):100-8. X-2, X-3, X-4. [pmid: 15090684].
1495 Chiras J, et al. Selective intra-arterial chemoembolization of pelvic and spine bone metastases. Eur Radiol. 2004;14(10):1774-80. X-2, X-3, X-4. [pmid: 15034742].
1496 Kart-Koseoglu H, et al. Osteoarthritis in hemodialysis patients: relationships with bone mineral density and other clinical and laboratory parameters. Rheumatol Int. 2005;25(4):270-5. X-2, X-3, X-4. [pmid: 14999425].
1497 Hocht S, et al. Recurrent rectal cancer within the pelvis. A multicenter analysis of 123 patients and recommendations for adjuvant radiotherapy. Strahlenther Onkol. 2004;180(1):15-20. X-2, X-3, X-4. [pmid: 14704840].
1498 Lopez MJ, Luna-Perez P. Composite pelvic exenteration: is it worthwhile?. Ann Surg Oncol. 2004;11(1):27-33. X-2, X-3, X-4. [pmid: 14699030].
1499 Lee KH, et al. Bone scintigraphy of skeletal metastasis in hepatoma patients treated by TAE. Hepatogastroenterology. 2003;50(54):1983-6. X-1, X-2, X-3, X-4. [pmid: 14696448].
1500 Wessalowski R, et al. An approach for cure: PEI-chemotherapy and regional deep hyperthermia in children and adolescents with unresectable malignant tumors. Klin Padiatr. 2003;215(6):303-9. X-2, X-3, X-4. [pmid: 14677093].
1501 Fuchs B, et al. Complications in long-term survivors of Ewing sarcoma. Cancer. 2003;98(12):2687-92. X-2, X-3, X-4. [pmid: 14669290].
1502 Feltelius N, Ekbom A, Blomqvist P. Cancer incidence among patients with ankylosing spondylitis in Sweden 1965-95: a population based cohort study. Ann Rheum Dis. 2003;62(12):1185-8. X-2, X-3, X-4. [pmid: 14644856].
1503 Loudiye H, et al. Hydatid disease of bone. Review of 11 cases. Joint Bone Spine. 2003;70(5):352-5. X-2, X-3, X-4. [pmid: 14563463].
1504 Delmas PD, et al. Severity of prevalent vertebral fractures and the risk of subsequent vertebral and nonvertebral fractures: results from the MORE trial. Bone. 2003;33(4):522-32. X-2, X-3, X-4. [pmid: 14555255].
1505 Hocht S, et al. Pelvic sidewall involvement in recurrent rectal cancer. Int J Colorectal Dis. 2004;19(2):108-13. X-2, X-3, X-4. [pmid: 14530995].
1506 Herrera A, Martinez AA. Extraspinal bone hydatidosis. J Bone Joint Surg Am. 2003;85-A(9):1790-4. X-2, X-3, X-4. [pmid: 12954839].
1507 Soderstrom M, et al. No improvement in the overall survival of 194 patients with chondrosarcoma in Finland in 1971-1990. Acta Orthop Scand. 2003;74(3):344-50. X-2, X-3, X-4. [pmid: 12899557].
1508 Neblett R, et al. Quantifying the lumbar flexion-relaxation phenomenon: theory, normative data, and clinical applications. Spine (Phila Pa 1976). 2003;28(13):1435-46. X-2, X-3, X-4. [pmid: 12838103].
1509 Tsirikos AI, et al. Comparison of one-stage versus two-stage anteroposterior spinal fusion in pediatric patients with cerebral palsy and neuromuscular scoliosis. Spine (Phila Pa 1976). 2003;28(12):1300-5. X-2, X-3, X-4. [pmid: 12811275].
1510 Laslett M, et al. Diagnosing painful sacroiliac joints: A validity study of a McKenzie evaluation and sacroiliac provocation tests. Aust J Physiother. 2003;49(2):89-97. X-2, X-3, X-4. [pmid: 12775204].
1511 Abbott KC, Bucci JR, Agodoa LY. Total hip arthroplasty in chronic dialysis patients in the United States. J Nephrol. 2003;16(1):34-9. X-2, X-3, X-4. [pmid: 12649533].
1512 Nakamoto Y, Osman M, Wahl RL. Prevalence and patterns of bone metastases detected with positron emission tomography using F-18 FDG. Clin Nucl Med. 2003;28(4):302-7. X-2, X-3, X-4. [pmid: 12642709].
1513 Fann AV. Validation of postural radiographs as a way to measure change in pelvic obliquity. Arch Phys Med Rehabil. 2003;84(1):75-8. X-2, X-3, X-4. [pmid: 12589624].
1514 Fan QY, et al. Bone tumors of the extremities or pelvis treated by microwave-induced hyperthermia. Clin Orthop Relat Res. 2003;(406):165-75. X-2, X-3, X-4. [pmid: 12579016].
1515 Fourney DR, et al. Thoracolumbopelvic stabilization for the treatment of instability caused by recurrent myxopapillary ependymoma. J Spinal Disord Tech. 2003;16(1):108-11. X-2, X-3, X-4. [pmid: 12571494].
1516 Bacci G, et al. Multimodal therapy for the treatment of nonmetastatic Ewing sarcoma of pelvis. J Pediatr Hematol Oncol. 2003;25(2):118-24. X-2, X-3, X-4. [pmid: 12571462].
1517 Pollock RC, et al. The swing procedure for pelvic ring reconstruction following tumour excision. Eur J Surg Oncol. 2003;29(1):59-63. X-2, X-3, X-4. [pmid: 12559078].
1518 Shafik A, El-Sibai O. Study of the levator ani muscle in the multipara: role of levator dysfunction in defecation disorders. J Obstet Gynaecol. 2002;22(2):187-92. X-2, X-3, X-4. [pmid: 12521706].
1519 de Paula F, et al. Clinical variability in calpainopathy: what makes the difference?. Eur J Hum Genet. 2002;10(12):825-32. X-2, X-3, X-4. [pmid: 12461690].
1520 Harrison DE, et al. Changes in sagittal lumbar configuration with a new method of extension traction: nonrandomized clinical controlled trial. Arch Phys Med Rehabil. 2002;83(11):1585-91. X-2, X-3, X-4. [pmid: 12422330].
1521 Grohs JG, et al. Benign fibrous histiocytoma of bone: a report of ten cases and review of literature. Wien Klin Wochenschr. 2002;114(1-2):56-63. X-2, X-3, X-4. [pmid: 12407938].
1522 Goldstein SR, Nanavati N. Adverse events that are associated with the selective estrogen receptor modulator levormeloxifene in an aborted phase III osteoporosis treatment study. Am J Obstet Gynecol. 2002;187(3):521-7. X-2, X-3, X-4. [pmid: 12237621].
1523 Estourgie SH, Nielsen GP, Ott MJ. Metastatic patterns of extremity myxoid liposarcoma and their outcome. J Surg Oncol. 2002;80(2):89-93. X-2, X-3, X-4. [pmid: 12173385].
1524 Treaba D, et al. Diagnostic role of fine-needle aspiration of bone lesions in patients with a previous history of malignancy. Diagn Cytopathol. 2002;26(6):380-3. X-2, X-3, X-4. [pmid: 12112828].
1525 Muller PE, et al. Internal hemipelvectomy and reconstruction with a megaprosthesis. Int Orthop. 2002;26(2):76-9. X-2, X-3, X-4. [pmid: 12078881].
1526 Sys G, et al. Extracorporeally irradiated autografts in pelvic reconstruction after malignant tumour resection. Int Orthop. 2002;26(3):174-8. X-2, X-3, X-4. [pmid: 12073112].
1527 Rogers J, Jeffrey DR, Watt I. Paget's disease in an archeological population. J Bone Miner Res. 2002;17(6):1127-34. X-2, X-3, X-4. [pmid: 12054169].
1528 Bohm P, Huber J. The surgical treatment of bony metastases of the spine and limbs. J Bone Joint Surg Br. 2002;84(4):521-9. X-2, X-3, X-4, X-5. [pmid: 12043772].
1529 Eggli S, Muller C, Ganz R. Revision surgery in pelvic discontinuity: an analysis of seven patients. Clin Orthop Relat Res. 2002;(398):136-45. X-2, X-3, X-4. [pmid: 11964643].
1530 Weber KL, Pring ME, Sim FH. Treatment and outcome of recurrent pelvic chondrosarcoma. Clin Orthop Relat Res. 2002;(397):19-28. X-2, X-3, X-4. [pmid: 11953591].
1531 Knutson GA. Incidence of foot rotation, pelvic crest unleveling, and supine leg length alignment asymmetry and their relationship to self-reported back pain. J Manipulative Physiol Ther. 2002;25(2):110E. X-2, X-3, X-4.
1532 Maenpaa HM, et al. Insufficiency fractures in patients with chronic inflammatory joint diseases. Clin Exp Rheumatol. 2002;20(1):77-9. X-2, X-3, X-4. [pmid: 11894837].
1533 Ozaki T, et al. Implantation of hemipelvic prosthesis after resection of sarcoma. Clin Orthop Relat Res. 2002;(396):197-205. X-2, X-3, X-4. [pmid: 11859244].
1534 Papagelopoulos PJ, et al. Treatment of aneurysmal bone cysts of the pelvis and sacrum. J Bone Joint Surg Am. 2001;83-A(11):1674-81. X-2, X-3, X-4. [pmid: 11701790].
1535 Yildiz Y, et al. The use of polymethylmethacrylate in the management of hydatid disease of bone. J Bone Joint Surg Br. 2001;83(7):1005-8. X-2, X-3, X-4. [pmid: 11603512].
1536 Wirbel RJ, Schulte M, Mutschler WE. Surgical treatment of pelvic sarcomas: oncologic and functional outcome. Clin Orthop Relat Res. 2001;(390):190-205. X-2, X-3, X-4. [pmid: 11550866].
1537 Stojkovic T, et al. Congenital myopathy with central cores and fingerprint bodies in association with malignant hyperthermia susceptibility. Neuromuscul Disord. 2001;11(6-7):538-41. X-2, X-3, X-4. [pmid: 11525882].
1538 Hyodoh K, Sugimoto H. Pustulotic arthro-osteitis: defining the radiologic spectrum of the disease. Semin Musculoskelet Radiol. 2001;5(2):89-93. X-1, X-2, X-3, X-4. [pmid: 11500146].
1539 Langlais F, Lambotte JC, Thomazeau H. Long-term results of hemipelvis reconstruction with allografts. Clin Orthop Relat Res. 2001;(388):178-86. X-2, X-3, X-4. [pmid: 11451117].
1540 Natarajan MV, et al. The Saddle prosthesis in periacetabular tumours. Int Orthop. 2001;25(2):107-9. X-2, X-3, X-4. [pmid: 11409447].
1541 Olivieri I, et al. Lack of association with spondyloarthritis and HLA-B27 in Italian patients with Whipple's disease. J Rheumatol. 2001;28(6):1294-7. X-2, X-3, X-4. [pmid: 11409122].
1542 Job-Deslandre C, Krebs S, Kahan A. Chronic recurrent multifocal osteomyelitis: five-year outcomes in 14 pediatric cases. Joint Bone Spine. 2001;68(3):245-51. X-2, X-3, X-4. [pmid: 11394625].
1543 Woertler K, et al. Osteoid osteoma: CT-guided percutaneous radiofrequency ablation and follow-up in 47 patients. J Vasc Interv Radiol. 2001;12(6):717-22. X-2, X-3, X-4. [pmid: 11389223].
1544 Bergh P, et al. Prognostic factors and outcome of pelvic, sacral, and spinal chondrosarcomas: a center-based study of 69 cases. Cancer. 2001;91(7):1201-12. X-2, X-3, X-4. [pmid: 11283918].
1545 Bentley G, et al. The treatment of scoliosis in muscular dystrophy using modified Luque and Harrington-Luque instrumentation. J Bone Joint Surg Br. 2001;83(1):22-8. X-2, X-3, X-4. [pmid: 11245532].
1546 Kageyama Y, et al. Preoperative concurrent chemoradiotherapy against muscle-invasive bladder cancer: results of partial cystectomy in elderly or high-risk patients. Jpn J Clin Oncol. 2000;30(12):553-6. X-2, X-3, X-4. [pmid: 11210165].
1547 Yokoyama R, et al. A multidisciplinary approach to the treatment of malignant pelvic bone tumors: results with eight consecutive patients. J Orthop Sci. 2000;5(5):449-56. X-2, X-3, X-4. [pmid: 11180901].
1548 Boechat MI, et al. Avascular necrosis of the femoral head in children with chronic renal disease. Radiology. 2001;218(2):411-3. X-2, X-3, X-4. [pmid: 11161154].
1549 Ennis RD, et al. The effect of cystectomy, and perioperative methotrexate, vinblastine, doxorubicin and cisplatin chemotherapy on the risk and pattern of relapse in patients with muscle invasive bladder cancer. J Urol. 2000;163(5):1413-8. X-2, X-3, X-4. [pmid: 10751847].
1550 Nagoya S, et al. Reconstruction and limb salvage using a free vascularised fibular graft for periacetabular malignant bone tumours. J Bone Joint Surg Br. 2000;82(8):1121-4. X-2, X-3, X-4. [pmid: 11132270].
1551 Marcy PY, et al. Percutaneous cementoplasty for pelvic bone metastasis. Support Care Cancer. 2000;8(6):500-3. X-2, X-3, X-4. [pmid: 11094996].
1552 Hirshberg J, et al. Osteomyelitis related to pressure ulcers: the cost of neglect. Adv Skin Wound Care. 2000;13(1):25-9. X-2, X-3, X-4. [pmid: 11061707].
1553 Sturzenbecher A, et al. MR imaging of septic sacroiliitis. Skeletal Radiol. 2000;29(8):439-46. X-2, X-3, X-4. [pmid: 11026711].
1554 Kollender Y, et al. Metastatic renal cell carcinoma of bone: indications and technique of surgical intervention. J Urol. 2000;164(5):1505-8. X-2, X-3, X-4. [pmid: 11025692].
1555 Inoue YZ, et al. Clinicopathologic features and treatment of postirradiation sarcoma of bone and soft tissue. J Surg Oncol. 2000;75(1):42-50. X-2, X-3, X-4. [pmid: 11025461].
1556 Ramappa AJ, et al. Chondroblastoma of bone. J Bone Joint Surg Am. 2000;82-A(8):1140-5. X-2, X-3, X-4. [pmid: 10954104].
1557 Teleky B. Abdomiosacral resection of recurrent rectal cancer in the sacrum. Acta Chir Iugosl. 1998;45(2 Suppl):45-7. X-1, X-2, X-3, X-4. [pmid: 10951787].
1558 Rantanen P, Nykvist F. Optimal sagittal motion axis for trunk extension and flexion tests in chronic low back trouble. Clin Biomech (Bristol, Avon). 2000;15(9):665-71. X-2, X-3, X-4.
1559 Ostensen M, Almberg K, Koksvik HS. Sex, reproduction, and gynecological disease in young adults with a history of juvenile chronic arthritis. J Rheumatol. 2000;27(7):1783-7. X-2, X-3, X-4. [pmid: 10914869].
1560 Mochizuki K, Yamaguchi H, Umeda T. The management of pelvic chondrosarcoma in Japan. Japanese Musculo-Skeletal Oncology Group. Int Orthop. 2000;24(2):65-70. X-2, X-3, X-4. [pmid: 10894372].
1561 Kollender Y, et al. Internal hemipelvectomy for bone sarcomas in children and young adults: surgical considerations. Eur J Surg Oncol. 2000;26(4):398-404. X-2, X-3, X-4. [pmid: 10873363].
1562 Papagelopoulos PJ, et al. Primary fibrosarcoma of bone. Outcome after primary surgical treatment. Clin Orthop Relat Res. 2000;(373):88-103. X-2, X-3, X-4. [pmid: 10810466].
1563 Zhuang H, et al. Exclusion of chronic osteomyelitis with F-18 fluorodeoxyglucose positron emission tomographic imaging. Clin Nucl Med. 2000;25(4):281-4. X-2, X-3, X-4. [pmid: 10750968].
1564 Renard AJ, et al. The saddle prosthesis in pelvic primary and secondary musculoskeletal tumors: functional results at several postoperative intervals. Arch Orthop Trauma Surg. 2000;120(3-4):188-94. X-2, X-3, X-4. [pmid: 10738881].
1565 Youdas JW, et al. Lumbar lordosis and pelvic inclination in adults with chronic low back pain. Phys Ther. 2000;80(3):261-75. X-2, X-3, X-4. [pmid: 10696153].
1566 Shiromizu K, et al. Clinicopathological study of recurrent uterine cervical squamous-cell carcinoma. J Obstet Gynaecol Res. 1999;25(6):395-9. X-2, X-3, X-4. [pmid: 10680336].
1567 Shankar AG, et al. Local therapy and other factors influencing site of relapse in patients with localised Ewing's sarcoma. United Kingdom Children's Cancer Study Group (UKCCSG). Eur J Cancer. 1999;35(12):1698-704. X-2, X-3, X-4. [pmid: 10674016].
1568 Zink A, et al. Malignant tumors in an ancient Egyptian population. Anticancer Res. 1999;19(5B):4273-7. X-2, X-3, X-4. [pmid: 10628386].
1569 MacDonald SJ, Hersche O, Ganz R. Periacetabular osteotomy in the treatment of neurogenic acetabular dysplasia. J Bone Joint Surg Br. 1999;81(6):975-8. X-2, X-3, X-4. [pmid: 10615968].
1570 Fidias P, et al. Long-term results of combined modality therapy in primary bone lymphomas. Int J Radiat Oncol Biol Phys. 1999;45(5):1213-8. X-2, X-3, X-4. [pmid: 10613315].
1571 Leopold SS, et al. Cementless acetabular revision. Evaluation at an average of 10.5 years. Clin Orthop Relat Res. 1999;(369):179-86. X-2, X-3, X-4. [pmid: 10611873].
1572 Berry DJ, et al. Pelvic discontinuity in revision total hip arthroplasty. J Bone Joint Surg Am. 1999;81(12):1692-702. X-2, X-3, X-4. [pmid: 10608380].
1573 Renard AJ, et al. Osteosarcoma: oncologic and functional results. A single institutional report covering 22 years. J Surg Oncol. 1999;72(3):124-9. X-2, X-3, X-4. [pmid: 10562357].
1574 Bauman WA, et al. Continuous loss of bone during chronic immobilization: a monozygotic twin study. Osteoporos Int. 1999;10(2):123-7. X-2, X-3, X-4. [pmid: 10501792].
1575 Guttentag AR, Salwen JK. Keep your eyes on the ribs: the spectrum of normal variants and diseases that involve the ribs. Radiographics. 1999;19(5):1125-42. X-1, X-2, X-3, X-4. [pmid: 10489169].
1576 McCarthy RE, Bruffett WL, McCullough FL. S rod fixation to the sacrum in patients with neuromuscular spinal deformities. Clin Orthop Relat Res. 1999;(364):26-31. X-2, X-3, X-4. [pmid: 10416388].
1577 Freedman GM, et al. Preliminary results of a bone marrow magnetic resonance imaging protocol for patients with high-risk prostate cancer. Urology. 1999;54(1):118-23. X-2, X-3, X-4. [pmid: 10414737].
1578 Arden NK, et al. Osteoarthritis and risk of falls, rates of bone loss, and osteoporotic fractures. Study of Osteoporotic Fractures Research Group. Arthritis Rheum. 1999;42(7):1378-85. X-2, X-3, X-4. [pmid: 10403265].
1579 Porsch M, Kornhuber B, Hovy L. Functional results after partial pelvic resection in Ewing's sarcoma of the ilium. Arch Orthop Trauma Surg. 1999;119(3-4):199-204. X-2, X-3, X-4. [pmid: 10392519].
1580 Stevens MA, et al. Imaging features of avulsion injuries. Radiographics. 1999;19(3):655-72. X-1, X-2, X-3, X-4. [pmid: 10336196].
1581 Hodsman AB, et al. The addition of a raloxifene analog (LY117018) allows for reduced PTH(1-34) dosing during reversal of osteopenia in ovariectomized rats. J Bone Miner Res. 1999;14(5):675-9. X-2, X-3, X-4. [pmid: 10320515].
1582 Fann AV, Lee R, Verbois GM. The reliability of postural x-rays in measuring pelvic obliquity. Arch Phys Med Rehabil. 1999;80(4):458-61. X-2, X-3, X-4. [pmid: 10206611].
1583 Lee FY, et al. Chondrosarcoma of bone: an assessment of outcome. J Bone Joint Surg Am. 1999;81(3):326-38. X-2, X-3, X-4. [pmid: 10199270].
1584 Saunders A, Davies AM, Grimer RJ. Magnetic resonance imaging of soft tissue expanders used in the management of musculoskeletal sarcomas. Br J Radiol. 1998;71(849):926-9. X-2, X-3, X-4. [pmid: 10195006].
1585 Hoffmann C, et al. Pelvic Ewing sarcoma: a retrospective analysis of 241 cases. Cancer. 1999;85(4):869-77. X-2, X-3, X-4. [pmid: 10091764].
1586 Ragab AA, Kraay MJ, Goldberg VM. Clinical and radiographic outcomes of total hip arthroplasty with insertion of an anatomically designed femoral component without cement for the treatment of primary osteoarthritis. A study with a minimum of six years of follow-up. J Bone Joint Surg Am. 1999;81(2):210-8. X-2, X-3, X-4. [pmid: 10073584].
1587 Jattiot F, et al. Fourteen cases of sarcomatous degeneration in Paget's disease. J Rheumatol. 1999;26(1):150-5. X-2, X-3, X-4. [pmid: 9918257].
1588 Bjornsson J, et al. Primary chondrosarcoma of long bones and limb girdles. Cancer. 1998;83(10):2105-19. X-2, X-3, X-4, X-5. [pmid: 9827715].
1589 Harrison DD, et al. Elliptical modeling of the sagittal lumbar lordosis and segmental rotation angles as a method to discriminate between normal and low back pain subjects. J Spinal Disord. 1998;11(5):430-9. X-2, X-3, X-4. [pmid: 9811104].
1590 Leroy JG, et al. Bruck syndrome: neonatal presentation and natural course in three patients. Pediatr Radiol. 1998;28(10):781-9. X-2, X-3, X-4. [pmid: 9799301].
1591 Pope MH, Magnusson M, Wilder DG. Kappa Delta Award. Low back pain and whole body vibration. Clin Orthop Relat Res. 1998;(354):241-8. X-2, X-3, X-4. [pmid: 9755785].
1592 Nilbert M, et al. Ewing's sarcoma treatment in Scandinavia 1984-1990--ten-year results of the Scandinavian Sarcoma Group Protocol SSGIV. Acta Oncol. 1998;37(4):375-8. X-2, X-3, X-4. [pmid: 9743460].
1593 Kennedy JG, et al. Effect of acetabular component orientation on recurrent dislocation, pelvic osteolysis, polyethylene wear, and component migration. J Arthroplasty. 1998;13(5):530-4. X-2, X-3, X-4. [pmid: 9726318].
1594 Oda Y, et al. Giant cell tumor of bone: oncological and functional results of long-term follow-up. Jpn J Clin Oncol. 1998;28(5):323-8. X-2, X-3, X-4. [pmid: 9703860].
1595 Azouz EM, Jurik AG, Bernard C. Sternocostoclavicular hyperostosis in children: a report of eight cases. AJR Am J Roentgenol. 1998;171(2):461-6. X-2, X-3, X-4. [pmid: 9694476].
1596 Guibaud L, et al. Aneurysmal bone cysts: percutaneous embolization with an alcoholic solution of zein--series of 18 cases. Radiology. 1998;208(2):369-73. X-2, X-3, X-4. [pmid: 9680561].
1597 Cerase A, Priolo F. Skeletal benign bone-forming lesions. Eur J Radiol. Suppl 1. 1998;27:S91-7. X-1, X-2, X-3, X-4. [pmid: 9652508].
1598 Sperling DC, et al. Deep pelvic abscesses: transperineal US-guided drainage. Radiology. 1998;208(1):111-5. X-2, X-3, X-4. [pmid: 9646800].
1599 Sugimoto H, Tamura K, Fujii T. The SAPHO syndrome: defining the radiologic spectrum of diseases comprising the syndrome. Eur Radiol. 1998;8(5):800-6. X-2, X-3, X-4. [pmid: 9601968].
1600 Huang AB, et al. Osteomyelitis of the pelvis/hips in paralyzed patients: accuracy and clinical utility of MRI. J Comput Assist Tomogr. 1998;22(3):437-43. X-2, X-3, X-4. [pmid: 9606387].
1601 Masterson EL, et al. Hindquarter amputation for pelvic tumors. The importance of patient selection. Clin Orthop Relat Res. 1998;(350):187-94. X-2, X-3, X-4. [pmid: 9602819].
1602 Schmalzried TP, Fowble VA, Amstutz HC. The fate of pelvic osteolysis after reoperation. No recurrence with lesional treatment. Clin Orthop Relat Res. 1998;(350):128-37. X-2, X-3, X-4. [pmid: 9602811].
1603 Kawai A, et al. Osteosarcoma of the pelvis. Oncologic results of 40 patients. Clin Orthop Relat Res. 1998;(348):196-207. X-2, X-3, X-4. [pmid: 9553553].
1604 Olney B, Latz K, Asher M. Treatment of hip dysplasia in older children with a combined one-stage procedure. Clin Orthop Relat Res. 1998;(347):215-23. X-2, X-3, X-4. [pmid: 9520893].
1605 Bollow M, et al. Use of dynamic magnetic resonance imaging to detect sacroiliitis in HLA-B27 positive and negative children with juvenile arthritides. J Rheumatol. 1998;25(3):556-64. X-2, X-3, X-4. [pmid: 9517781].
1606 Smith SE, Estok DM 2nd, Harris WH. Average 12-year outcome of a chrome-cobalt, beaded, bony ingrowth acetabular component. J Arthroplasty. 1998;13(1):50-60. X-2, X-3, X-4. [pmid: 9493538].
1607 Vikram B, et al. Rapidly alternating chemotherapy and radiotherapy instead of cystectomy for the treatment of muscle-invasive carcinoma of the urinary bladder: long term results of a pilot study. Cancer. 1998;82(5):918-22. X-2, X-3, X-4. [pmid: 9486582].
1608 Kawai A, et al. Prognostic factors for patients with sarcomas of the pelvic bones. Cancer. 1998;82(5):851-9. X-2, X-3, X-4. [pmid: 9486573].
1609 Bollow M, et al. Normal morphology of sacroiliac joints in children: magnetic resonance studies related to age and sex. Skeletal Radiol. 1997;26(12):697-704. X-2, X-3, X-4. [pmid: 9453102].
1610 Smith SE, Harris WH. Total hip arthroplasty performed with insertion of the femoral component with cement and the acetabular component without cement. Ten to thirteen-year results. J Bone Joint Surg Am. 1997;79(12):1827-33. X-2, X-3, X-4. [pmid: 9409796].
1611 Bell RS, et al. Allograft reconstruction of the acetabulum after resection of stage-IIB sarcoma. Intermediate-term results. J Bone Joint Surg Am. 1997;79(11):1663-74. X-2, X-3, X-4. [pmid: 9384426].
1612 Maloney WJ, et al. Treatment of pelvic osteolysis associated with a stable acetabular component inserted without cement as part of a total hip replacement. J Bone Joint Surg Am. 1997;79(11):1628-34. X-2, X-3, X-4. [pmid: 9384421].
1613 Gonzalez T, et al. Erosive azotemic osteoarthropathy of the hands in chronic ambulatory peritoneal dialysis and hemodialysis. Clin Exp Rheumatol. 1997;15(4):367-71. X-2, X-3, X-4. [pmid: 9272296].
1614 Franz A, et al. Mycoplasmal arthritis in patients with primary immunoglobulin deficiency: clinical features and outcome in 18 patients. Br J Rheumatol. 1997;36(6):661-8. X-2, X-3, X-4. [pmid: 9236676].
1615 Jimenez-Balderas FJ, et al. Does serum rheumatoid factor have an influence on the clinical picture of ankylosing spondylitis?. Clin Exp Rheumatol. 1997;15(3):289-93. X-2, X-3, X-4. [pmid: 9177924].
1616 Ozaki T, et al. Chondrosarcoma of the pelvis. Clin Orthop Relat Res. 1997;(337):226-39. X-2, X-3, X-4. [pmid: 9137194].
1617 Dias RC, et al. Revision spine surgery in children with cerebral palsy. J Spinal Disord. 1997;10(2):132-44. X-2, X-3, X-4. [pmid: 9113612].
1618 Carroll K, Coleman S, Stevens PM. Coxa vara: surgical outcomes of valgus osteotomies. J Pediatr Orthop. 1997;17(2):220-4. X-2, X-3, X-4. [pmid: 9075100].
1619 Huang SC, Wang JH. A comparative study of nonoperative versus operative treatment of developmental dysplasia of the hip in patients of walking age. J Pediatr Orthop. 1997;17(2):181-8. X-2, X-3, X-4. [pmid: 9075093].
1620 Giurea A, et al. The benefits of surgery in the treatment of pelvic metastases. Int Orthop. 1997;21(5):343-8. X-2, X-3, X-4. [pmid: 9476167].
1621 Rahoty P, Szendroi M. Tumor surgery of the pelvic region. Acta Chir Hung. 1997;36(1-4):284-5. X-2, X-3, X-4. [pmid: 9408376].
1622 Soulen RL, et al. Musculoskeletal complications of neutron therapy for prostate cancer. Radiat Oncol Investig. 1997;5(2):81-91. X-2, X-3, X-4.
1623 Clauw DJ, et al. The relationship between fibromyalgia and interstitial cystitis. J Psychiatr Res. 1997;31(1):125-31. X-2, X-3, X-4, X-5. [pmid: 9201654].
1624 Toussirot E, Dupond JL, Wendling D. Spondylodiscitis in SAPHO syndrome. A series of eight cases. Ann Rheum Dis. 1997;56(1):52-8. X-2, X-3, X-4. [pmid: 9059142].
1625 O'Connor MI. Malignant pelvic tumors: limb-sparing resection and reconstruction. Semin Surg Oncol. 1997;13(1):49-54. X-1, X-2, X-3, X-4. [pmid: 9025182].
1626 Goldberg VM, et al. Hybrid total hip arthroplasty: a 7- to 11-year followup. Clin Orthop Relat Res. 1996;(333):147-54. X-2, X-3, X-4. [pmid: 8981890].
1627 Dinc H, et al. Percutaneous catheter drainage of tuberculous and nontuberculous psoas abscesses. Eur J Radiol. 1996;23(2):130-4. X-2, X-3, X-4. [pmid: 8886725].
1628 Sheth DS, et al. Chondrosarcoma of the pelvis. Prognostic factors for 67 patients treated with definitive surgery. Cancer. 1996;78(4):745-50. X-2, X-3, X-4. [pmid: 8756367].
1629 Uthman I, Vazquez-Abad D, Senecal JL. Distinctive features of idiopathic inflammatory myopathies in French Canadians. Semin Arthritis Rheum. 1996;26(1):447-58. X-2, X-3, X-4. [pmid: 8870112].
1630 Browner WS, et al. Mortality following fractures in older women. The study of osteoporotic fractures. Arch Intern Med. 1996;156(14):1521-5. X-2, X-3, X-4. [pmid: 8687260].
1631 Ashamalla HL, Thom SR, Goldwein JW. Hyperbaric oxygen therapy for the treatment of radiation-induced sequelae in children. The University of Pennsylvania experience. Cancer. 1996;77(11):2407-12. X-2, X-3, X-4. [pmid: 8635114].
1632 Barrie JL, Galasko CS. Surgery for unstable hips in cerebral palsy. J Pediatr Orthop B. 1996;5(4):225-31. X-2, X-3, X-4. [pmid: 8897253].
1633 Burger R, et al. Median corpectomy in cervical spondylotic multisegmental stenosis. Zentralbl Neurochir. 1996;57(2):62-9. X-2, X-3, X-4. [pmid: 8779271].
1634 Sengelov L, Kamby C, von der Maase H. Pattern of metastases in relation to characteristics of primary tumor and treatment in patients with disseminated urothelial carcinoma. J Urol. 1996;155(1):111-4. X-2, X-3, X-4. [pmid: 7490804].
1635 Hoekstra HJ, et al. Hemipelvectomy and intraoperative radiotherapy for bone and soft tissue sarcomas of the pelvic girdle. Radiother Oncol. 1995;37(2):160-3. X-2, X-3, X-4. [pmid: 8747941].
1636 Malone S, et al. Long-term follow-up of efficacy and safety of megavoltage radiotherapy in high-risk giant cell tumors of bone. Int J Radiat Oncol Biol Phys. 1995;33(3):689-94. X-2, X-3, X-4. [pmid: 7558960].
1637 Malawer MM, Chou LB. Prosthetic survival and clinical results with use of large-segment replacements in the treatment of high-grade bone sarcomas. J Bone Joint Surg Am. 1995;77(8):1154-65. X-2, X-3, X-4. [pmid: 7642659].
1638 Borges JL, Kumar SJ, Guille JT. Congenital dislocation of the hip in boys. J Bone Joint Surg Am. 1995;77(7):975-84. X-2, X-3, X-4. [pmid: 7608240].
1639 Brenner PC, et al. TAG-72 expression in primary, metastatic and hormonally treated prostate cancer as defined by monoclonal antibody CC49. J Urol. 1995;153(5):1575-9. X-2, X-3, X-4. [pmid: 7536270].
1640 Bradford MS, Paprosky WG. Acetabular defect classification: a detailed radiographic approach. Semin Arthroplasty. 1995;6(2):76-85. X-1, X-2, X-3, X-4. [pmid: 10155692].
1641 Christie HJ, Kumar S, Warren SA. Postural aberrations in low back pain. Arch Phys Med Rehabil. 1995;76(3):218-24. X-2, X-3, X-4. [pmid: 7717811].
1642 Hollingworth P. Differential diagnosis and management of hip pain in childhood. Br J Rheumatol. 1995;34(1):78-82. X-1, X-2, X-3, X-4. [pmid: 7881844].
1643 van Loon CJ, et al. Chondrosarcoma of bone: oncologic and functional results. J Surg Oncol. 1994;57(4):214-21. X-2, X-3, X-4. [pmid: 7990475].
1644 Patel SR, et al. Myxoid liposarcoma. Experience with chemotherapy. Cancer. 1994;74(4):1265-9. X-2, X-3, X-4. [pmid: 8055448].
1645 Marcove RC, et al. Conservative surgery for giant cell tumors of the sacrum. The role of cryosurgery as a supplement to curettage and partial excision. Cancer. 1994;74(4):1253-60. X-2, X-3, X-4. [pmid: 8055446].
1646 Safran MR, et al. 151 endoprosthetic reconstructions for patients with primary tumors involving bone. Contemp Orthop. 1994;29(1):15-25. X-2, X-3, X-4. [pmid: 10172089].
1647 Taconis WK, Schutte HE, van der Heul RO. Desmoplastic fibroma of bone: a report of 18 cases. Skeletal Radiol. 1994;23(4):283-8. X-2, X-3, X-4. [pmid: 8059254].
1648 Ratanatharathorn V, et al. Bone metastasis from cervical cancer. Cancer. 1994;73(9):2372-9. X-2, X-3, X-4. [pmid: 7513250].
1649 Partin AW, et al. Evaluation of serum prostate-specific antigen velocity after radical prostatectomy to distinguish local recurrence from distant metastases. Urology. 1994;43(5):649-59. X-2, X-3, X-4. [pmid: 7513108].
1650 Fairbanks RK, et al. Treatment of stage IE primary lymphoma of bone. Int J Radiat Oncol Biol Phys. 1994;28(2):363-72. X-2, X-3, X-4. [pmid: 8276651].
1651 Hugenholtz EA, et al. Bone scintigraphy in nonsurgically treated Ewing's sarcoma at diagnosis and follow-up: prognostic information of the primary tumor site. Med Pediatr Oncol. 1994;22(4):236-9. X-2, X-3, X-4. [pmid: 8107653].
1652 Sanjay BK, et al. Treatment of giant-cell tumor of the pelvis. J Bone Joint Surg Am. 1993;75(10):1466-75. X-2, X-3, X-4. [pmid: 8408135].
1653 Yokoyama R, et al. Prognostic factors of malignant fibrous histiocytoma of bone. A clinical and histopathologic analysis of 34 cases. Cancer. 1993;72(6):1902-8. X-2, X-3, X-4. [pmid: 8364866].
1654 Mankey MG, Arntz GT, Staheli LT. Open reduction through a medial approach for congenital dislocation of the hip. A critical review of the Ludloff approach in sixty-six hips. J Bone Joint Surg Am. 1993;75(9):1334-45. X-2, X-3, X-4. [pmid: 8408154].
1655 Tan RK. Use of skeletal surveys in the radiological assessment of renal osteodystrophy--a study in the Singapore General Hospital. Ann Acad Med Singapore. 1993;22(5):714-9. X-2, X-3, X-4. [pmid: 8267351].
1656 Bohm B, et al. Our approach to the management of congenital presacral tumors in adults. Int J Colorectal Dis. 1993;8(3):134-8. X-2, X-3, X-4. [pmid: 8245668].
1657 Cola A, et al. Anesthesia and perioperative treatment in large resections of the pelvic girdle. Chir Organi Mov. 1993;78(2):111-7. X-2, X-3, X-4. [pmid: 8344072].
1658 Borg MF, et al. Bone involvement in Hodgkin's disease. Australas Radiol. 1993;37(1):63-6. X-2, X-3, X-4. [pmid: 8323514].
1659 Douglass EC, et al. Alveolar rhabdomyosarcoma with the t(2;13): cytogenetic findings and clinicopathologic correlations. Med Pediatr Oncol. 1993;21(2):83-7. X-2, X-3, X-4. [pmid: 8433683].
1660 Doody MM, et al. Leukemia, lymphoma, and multiple myeloma following selected medical conditions. Cancer Causes Control. 1992;3(5):449-56. X-2, X-3, X-4. [pmid: 1525326].
1661 Garland DE, et al. Osteoporosis after spinal cord injury. J Orthop Res. 1992;10(3):371-8. X-2, X-3, X-4. [pmid: 1569500].
1662 Temple WJ, Ketcham AS. Sacral resection for control of pelvic tumors. Am J Surg. 1992;163(4):370-4. X-2, X-3, X-4. [pmid: 1373043].
1663 Olivieri I, et al. Low frequency of axial involvement in Caucasian pediatric patients with seronegative enthesopathy and arthropathy syndrome after 5 years of disease. J Rheumatol. 1992;19(3):469-75. X-2, X-3, X-4. [pmid: 1578464].
1664 Estrada-Aguilar J, et al. Primary treatment of pelvic osteosarcoma. Report of five cases. Cancer. 1992;69(5):1137-45. X-2, X-3, X-4. [pmid: 1371232].
1665 Zulfikar B, Gedikoglu G. Ewing's sarcoma: experience with 12 cases. J Chemother. 1992;4(1):50-5. X-2, X-3, X-4. [pmid: 1403071].
1666 Marini M, et al. Progress of brown tumors in patients with chronic renal insufficiency undergoing dialysis. Eur J Radiol. 1992;14(1):67-71. X-2, X-3, X-4. [pmid: 1563408].
1667 De Cristofaro R, et al. Selective arterial embolization in the treatment of aneurysmal bone cyst and angioma of bone. Skeletal Radiol. 1992;21(8):523-7. X-2, X-3, X-4. [pmid: 1465646].
1668 Jacobson AF, Gilles CP, Cerqueira MD. Photopenic defects in marrow-containing skeleton on indium-111 leucocyte scintigraphy: prevalence at sites suspected of osteomyelitis and as an incidental finding. Eur J Nucl Med. 1992;19(10):858-64. X-2, X-3, X-4. [pmid: 1451701].
1669 Szendroi M, et al. Aneurysmal bone cyst. A review of 52 primary and 16 secondary cases. Arch Orthop Trauma Surg. 1992;111(6):318-22. X-2, X-3, X-4. [pmid: 1449939].
1670 Kivioja AH, et al. Surgical treatment of myeloma of bone. Eur J Cancer. 1992;28A(11):1865-9. X-2, X-3, X-4. [pmid: 1389528].
1671 Bacci G, et al. Non-metastatic Ewing's sarcoma: results in 98 patients treated with neoadjuvant chemotherapy. Ital J Orthop Traumatol. 1991;17(4):449-65. X-2, X-3, X-4. [pmid: 1816151].
1672 Misasi N, Sadile F. Selective arterial embolization in orthopaedic pathology. Analysis of long-term results. Chir Organi Mov. 1991;76(4):311-6. X-2, X-3, X-4. [pmid: 1800042].
1673 Fricker PA, Taunton JE, Ammann W. Osteitis pubis in athletes. Infection, inflammation or injury?. Sports Med. 1991;12(4):266-79. X-2, X-3, X-4. [pmid: 1784877].
1674 Gradinger R, Rechl H, Hipp E. Pelvic osteosarcoma. Resection, reconstruction, local control, and survival statistics. Clin Orthop Relat Res. 1991;(270):149-58. X-2, X-3, X-4. [pmid: 1884534].
1675 Evans RG, et al. Multimodal therapy for the management of localized Ewing's sarcoma of pelvic and sacral bones: a report from the second intergroup study. J Clin Oncol. 1991;9(7):1173-80. X-2, X-3, X-4. [pmid: 2045857].
1676 Berger MS, et al. The risks of metastases from shunting in children with primary central nervous system tumors. J Neurosurg. 1991;74(6):872-7. X-2, X-3, X-4. [pmid: 2033446].
1677 Fredin H, et al. Total hip arthroplasty in high congenital dislocation. 21 hips with a minimum five-year follow-up. J Bone Joint Surg Br. 1991;73(3):430-3. X-2, X-3, X-4. [pmid: 1670444].
1678 Christensen WN, et al. Prostatic duct adenocarcinoma. Findings at radical prostatectomy. Cancer. 1991;67(8):2118-24. X-2, X-3, X-4. [pmid: 2004331].
1679 Greene WB, et al. Musculoskeletal problems in association with cloacal exstrophy. J Bone Joint Surg Am. 1991;73(4):551-60. X-2, X-3, X-4. [pmid: 2013594].
1680 Campanacci M, Capanna R. Pelvic resections: the Rizzoli Institute experience. Orthop Clin North Am. 1991;22(1):65-86. X-2, X-3, X-4, X-5. [pmid: 1992435].
1681 Sciuk J, et al. Comparison of technetium 99m polyclonal human immunoglobulin and technetium 99m monoclonal antibodies for imaging chronic osteomyelitis. First clinical results. Eur J Nucl Med. 1991;18(6):401-7. X-2, X-3, X-4. [pmid: 1879446].
1682 Capanna R, et al. Hemipelvectomy in malignant neoplasms of the hip region. Ital J Orthop Traumatol. 1990;16(4):425-37. X-2, X-3, X-4. [pmid: 1712349].
1683 Olivieri I, et al. Differential diagnosis between osteitis condensans ilii and sacroiliitis. J Rheumatol. 1990;17(11):1504-12. X-2, X-3, X-4. [pmid: 2273492].
1684 Das AK, et al. Primary carcinoma of the upper urinary tract. Effect of primary and secondary therapy on survival. Cancer. 1990;66(9):1919-23. X-2, X-3, X-4. [pmid: 2224787].
1685 Nesbit ME Jr, et al. Multimodal therapy for the management of primary, nonmetastatic Ewing's sarcoma of bone: a long-term follow-up of the First Intergroup study. J Clin Oncol. 1990;8(10):1664-74. X-2, X-3, X-4. [pmid: 2213103].
1686 Kronwith SD, et al. Stickler's syndrome in the Cleft Palate Clinic. J Pediatr Ophthalmol Strabismus. 1990;27(5):265-7. X-2, X-3, X-4. [pmid: 2246742].
1687 Olivieri I, et al. Computed tomography of the sacroiliac joints in four patients with Behcet's syndrome--confirmation of sacroiliitis. Br J Rheumatol. 1990;29(4):264-7. X-2, X-3, X-4. [pmid: 2379043].
1688 Terz JJ, et al. Translumbar amputation. Cancer. 1990;65(12):2668-75. X-2, X-3, X-4. [pmid: 2340466].
1689 Foley M, et al. Distant metastases following surgical treatment of cervical carcinoma. Ir Med J. 1990;83(2):62-4. X-2, X-3, X-4. [pmid: 2391212].
1690 Kaplan ID, et al. Reduction of spinal metastases after preemptive irradiation in prostatic cancer. Int J Radiat Oncol Biol Phys. 1990;18(5):1019-25. X-2, X-3, X-4. [pmid: 2347712].
1691 Pettit CK, et al. Primary lymphoma of bone. A B-cell neoplasm with a high frequency of multilobated cells. Am J Surg Pathol. 1990;14(4):329-34. X-2, X-3, X-4. [pmid: 2321697].
1692 Sham JS, et al. Nasopharyngeal carcinoma: pattern of skeletal metastases. Br J Radiol. 1990;63(747):202-5. X-2, X-3, X-4. [pmid: 2334832].
1693 Roberson JR, Cohen D. Bipolar components for severe periacetabular bone loss around the failed total hip arthroplasty. Clin Orthop Relat Res. 1990;(251):113-8. X-2, X-3, X-4. [pmid: 2295161].
1694 Capanna R, et al. Ewing's sarcoma of the pelvis. Int Orthop. 1990;14(1):57-61. X-2, X-3, X-4. [pmid: 2341215].
1695 Swanson KJ, Pickett K, Konczak J. A clinical profile of female athletes with and without patellofemoral pain: a Postural Restoration Institute approach. Journal of Orthopaedic & Sports Physical Therapy. 2009;39(1):A114-A114. X-2, X-3, X-4.
1696 Kobe A, et al. A follow-up study of clients with Chiari pelvic osteotomy. Journal of Physical Therapy Science. 1997;9(1):15-18. X-2, X-3, X-4.
1697 Mackenzie N. A phenomenological study of women who presented to a physiotherapy-led continence service with dyspareunia and were treated with trigger point massage. Journal of the Association of Chartered Physiotherapists in Women's Health. 2009;(105):24-39. X-2, X-3, X-4.
1698 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. Journal of Back & Musculoskeletal Rehabilitation. 2006;19(4):111-117. X-2, X-3, X-4.
1699 Dulhunty J. A preliminary study of a sacral base obliquity measured on erect radiographs taken in a clinical setting. Chiropractic Journal of Australia. 2004;34(2):68-75. X-4.
1700 Silva MP, Barrett JM, Williams JD. A retrospective review of outcomes of fibromyalgia patients following physical therapy treatments. Journal of Musculoskeletal Pain. 2004;12(2):83-92. X-2, X-3, X-4.
1701 Goldsmith E, et al. A technique to measure windswept deformity. Physiotherapy. 1992;78(4):235-242. X-2, X-3, X-4.
1702 Novoseltsev SV, Vcherashny DB. Biomechanical disorders in the patients with lumbar discal hernias and their osteopathic correction. AAO Journal. 2010;20(1):11-15. X-1, X-2, X-3, X-4.
1703 Normand MC, et al. Biomechanical effects of a lumbar support in a mattress. Journal of the Canadian Chiropractic Association. 2005;49(2):96-101. X-2, X-3, X-4. [pmid: 17549199].
1704 Moore J, et al. Changes in femoral nerve H-reflex following lymbopelvic manipulation in subjects with patellofemoral pain syndrome. Journal of Orthopaedic & Sports Physical Therapy. 2009;39(1):A106-A106. X-2, X-3, X-4.
1705 Kivioja A, et al. Chondrosarcoma in a family with multiple hereditary exostoses. Journal of Bone & Joint Surgery, British Volume. 2000;82B(2):261-266. X-2, X-3, X-4.
1706 Unger JF Jr, Provencher S, DeCamp ON. Cranial distortion and category II pelvic blocking: a pilot study. Journal of Vertebral Subluxation Research (JVSR). 2009:1-11. X-2, X-3, X-4.
1707 Sutlive TG, et al. Development of a clinical prediction rule for diagnosing hip osteoarthritis in patients with unilateral hip pain. 2008 Combined Sections Meeting. Nashville, Tennessee. February 6-9, 2008. Journal of Orthopaedic & Sports Physical Therapy. 2008;38(1):A13-4. X-2, X-3, X-4.
1708 Gamboian N, et al. Effect of dance technique training and somatic training on pelvic tilt and lumbar lordosis alignment during quiet stance and dynamic dance movement. Journal of Dance Medicine & Science. 1999;3(1):5-14. X-2, X-3, X-4.
1709 Barnes MF, et al. Efficacy study of the effect of a myofascial release treatment technique on obtaining pelvic symmetry. Journal of Bodywork & Movement Therapies. 1997;1(5):289-296. X-3.
1710 Slane PR, Bull PW. Femur head height error on AP pelvic X-rays with alterations of source-to-image distance, central ray position, and object-to-film distance. Chiropractic Journal of Australia. 2006;36(2):46-50. X-2, X-3, X-4.
1711 Gamboian N, Chatfield SJ, Woollacott MH. Further effects of somatic training on pelvic tilt and lumbar lordosis alignment during quiet stance and dynamic dance movement. Journal of Dance Medicine & Science. 2000;4(3):90-98. X-2, X-3, X-4.
1712 Currie T, Berthelet E, Liu M. In the clinic. CT simulation for palliative patients. Radiation Therapist. 2002;11(2):169-173. X-2, X-3, X-4, X-5.
1713 Kissling RO, Waldis MF, Tschopp A. Is the geometry of the lumbosacral transition clinically relevant?. Journal of Manual & Manipulative Therapy (Journal of Manual & Manipulative Therapy). 1994;2(3):102-111. X-2, X-3, X-4.
1714 Dorman TA, et al. Muscles and pelvic clutch: hip abductor inhibition in anterior rotation of the ilium. Journal of Manual & Manipulative Therapy (Journal of Manual & Manipulative Therapy). 1995;3(3):85-90. X-2, X-3, X-4.
1715 Rodríguez-Pla A, et al. Osteitis condensans Ilii: a cause of low back pain? A case-controlled, retrospective study. Journal of Musculoskeletal Pain. 2004;12(2):65-70. X-2, X-3, X-4.
1716 Archbold HAP, et al. Patient specific cup anteversion in total hip arthroplasty: a computed tomography study investigating the use of the transverse acetabular ligament to control cup placement. Current Orthopaedic Practice. 2009;20(1):73-76. X-2, X-3, X-4.
1717 Bullock-Saxton J. Postural alignment in standing: a repeatability study. Australian Journal of Physiotherapy. 1993;39(1):25-29. X-2, X-3, X-4, X-5.
1718 Shabas D, Weinreb H. Preventive healthcare in women with multiple sclerosis. Journal of Women's Health & Gender-Based Medicine. 2000;9(4):389-395. X-2, X-3, X-4.
1719 Donovan C, et al. Relationship between bone density and balance measurement in women with osteoporosis: a preliminary study. Issues on Aging. 2000;23(2):3-8. X-2, X-3, X-4.
1720 Nguyen AD, et al. Relationships between lower extremity alignment and the quadriceps angle…. Patellofemoral pain syndrome: proximal, distal, and local factors, an international research retreat. April 30-May 2, 2009. Fells Point, Baltimore, MD. Journal of Orthopaedic & Sports Physical Therapy. 2010;40(3):A33-A33. X-2, X-3, X-4.
1721 Mavcic B, et al. Repeatability of biomechanical computations based on pelvic radiographic measurements of adult dysplastic hips. Current Orthopaedic Practice. 2009;20(5):557-560. X-2, X-3, X-4.
1722 Beals RB. Resident's forum. The possible effects of solid ankle-foot orthoses on trunk posture in the nonambulatory cerebral palsy population: a preliminary evaluation. Journal of Prosthetics & Orthotics (JPO). 2001;13(2):34-38. X-2, X-3, X-4.
1723 Basobas L, et al. Selective anterior fusion and instrumentation for the treatment of neuromuscular scoliosis. Spine. 2003;28(20S):S245-8. X-2, X-3, X-4. [pmid: 14560199].
1724 Troelsen A. Surgical advances in periacetabular osteotomy for treatment of hip dysplasia in adults. Acta Orthopaedica (Supplement). 2009;80:1-33. X-2, X-3, X-4. [pmid: 19757731].
1725 Buyukdereli G, et al. Technetium-99m-MIBI uptake in bone metastases: a comparative study with technetium-99m-MDP. Journal of Women's Imaging. 2005;7(2):65. X-2, X-3, X-4.
1726 Levine D, Walker JR, Tillman LJ. The effect of abdominal muscle strengthening on pelvic tilt and lumbar lordosis. Physiotherapy Theory & Practice. 1997;13(3):217-226. X-2, X-3, X-4.
1727 Noehren B, Davis I. The effect of gait retraining on hip mechanics, pain, and function in runners with patellofemoral pain syndrome…. Patellofemoral pain syndrome: proximal, distal, and local factors, an international research retreat. April 30-May 2, 2009. Fells Point, Baltimore, MD. Journal of Orthopaedic & Sports Physical Therapy. 2010;40(3):A40-1. X-2, X-3, X-4.
1728 McMeeken J, et al. The effect of spinal and pelvic posture and mobility on back pain in young dancers and non-dancers. Journal of Dance Medicine & Science. 2002;6(3):79-86. X-2, X-3, X-4.
1729 Fryer G, McPherson HC, O'Keefe P. The effect of training on the inter-examiner and intra-examiner reliability of the seated flexion test and assessment of pelvic anatomical landmarks with palpation. International Journal of Osteopathic Medicine. 2005;8(4):131-138. X-2, X-3, X-4.
1730 Levine D, et al. The effects of the five ballet foot positions on posture of the lumbar spine, pelvis, and hip…. 2008 Combined Sections Meeting…. Nashville, Tennessee. February 6-9, 2008. Journal of Orthopaedic & Sports Physical Therapy. 2008;38(1):A54-A54. X-1, X-2, X-3, X-4.
1731 Porter DE, Benson MK, Hosney GA. The hip in hereditary multiple exostoses. Journal of Bone & Joint Surgery, British Volume. 2001;83B(7):988-995. X-2, X-3, X-4.
1732 Gillman SC. The impact of chiropractic manipulative therapy on chronic recurrent lateral ankle sprain syndrome in two young athletes. Journal of Chiropractic Medicine. 2004;3(4):153-159. X-2, X-3, X-4. [pmid: 19674638].
1733 Kroll PG, et al. The relationship between lumbar lordosis and pelvic tilt angle. Journal of Back & Musculoskeletal Rehabilitation. 2000;14(1/2):21-25. X-2, X-3, X-4.
1734 Egan D, Cole J, Twomey L. The standing forward flexion test: an innaccurate determinant of sacroiliac joint dysfunction. Physiotherapy. 1996;82(4):236-242. X-2, X-3, X-4.
1735 Hartmann D, Strauhal MJ, Nelson CA. Treatment of women in the United States with localized, provoked vulvodynia: practice survey of women's health physical therapists. reprinted with permission from Hartman D [sic], Strauhal MJ, Nelson CA. Treatment of women in the United States with localized provoked vulvodynia. J Reprod Med. 2007; 52:48-52. Journal of Women's Health Physical Therapy. 2007;31(3):34-38. X-2, X-3.
1736 Ressel O, Rudy R. Vertebral subluxation correlated with somatic, visceral and immune complaints: an analysis of 650 children under chiropractic care. Journal of Vertebral Subluxation Research (JVSR). 2004:23. X-2, X-3, X-4.
1737 Hiers RH, et al. Hiding in plain sight: A case of Tarlov perineural cysts. The Journal of Pain. 2010;11(9):833-837. X-2, X-3, X-4. [pmid: 20800797].
1738 Rawicki B, et al. Botulinum toxin assessment, intervention and aftercare for paediatric and adult niche indications including pain: International consensus statement. European Journal of Neurology. 2010;17(Suppl 2):122-134. X-2, X-3, X-4. [pmid: 20633183].
1739 Park IU, et al. Retesting for repeat chlamydial infection: Family planning provider knowledge, attitudes, and practices. Journal of Women's Health. 2010;19(6):1139-1144. X-2, X-3, X-4.
1740 Bayram GO, Beji NK. Psychosexual adaptation and quality of life after hysterectomy. Sexuality and Disability. 2010;28(1):3-13. X-1, X-2, X-3, X-4, X-5.
1741 Weijenborg PTM, ter Kuile MM, Stones W. A cognitive behavioural based assessment of women with chronic pelvic pain. Journal of Psychosomatic Obstetrics & Gynecology. 2009;30(4):262-268. X-1, X-3, X-4, X-5. [pmid: 19922399].
1742 Xiaolin Z, et al. Transcatheter Intraarterial Methotrexate Infusion Combined with Selective Uterine Artery Embolization as a Treatment Option for Cervical Pregnancy. Journal of Vascular and Interventional Radiology. 2010;21(6):836-841. X-2, X-3, X-4. [pmid: 20400332].
1743 Hudelist G, et al. Administration of betaHCG leads to dose-dependent changes of gene expression signature of endometriotic stromal cells. Reproductive BioMedicine Online. 2010;20(5):699-706. X-2, X-3, X-4. [pmid: 20395176].
1744 Manero MG, et al. Thrombospondin-1 serum levels do not correlate with pelvic pain in patients with ovarian endometriosis. Journal of Ovarian Research. 2009;2(1). X-4.
1745 Cheung E, et al. Oral Fenretinide in biochemically recurrent prostate cancer: A California cancer consortium phase II trial. Clinical Genitourinary Cancer. 2009;7(1):43-50. X-2, X-3, X-4. [pmid: 19213668].
1746 Kosmas C, et al. Evaluation of the paclitaxel-ifosfamide-cisplatin (TIP) combination in relapsed and/or metastatic cervical cancer. British Journal of Cancer. 2009;101(7):1059-1065. X-2, X-3, X-4. [pmid: 19738606].
1747 Giovannoni MP, et al. PDE5 inhibitors and their applications. Current Medicinal Chemistry. 2010;17(24):2564-2587. X-1, X-2, X-3, X-4. [pmid: 20491634].
1748 Suzuki N, et al. GnRH receptor and peritoneal plasmin activity. Gynecological Endocrinology. 2010;26(9):669-672. X-2, X-3, X-4. [pmid: 20236028].
1749 Roberto KA, Ermann LS, Savla J. Older women's assessment and management of chronic pain in their daily lives. Journal of Pain Management. 2009;1(4):345-356. X-2, X-3, X-4.
1750 Merritt AL, et al. Gluteal-sparing approach for posterior iliac crest bone graft: Description of a new technique and assessment of morbidity in ninety-two patients after spinal fusion. Spine. 2010;35(14):1396-1400. X-2, X-3, X-4. [pmid: 20551786].
1751 Robinson GM, et al. Misuse of over-the-counter codeine-containing analgesics: Dependence and other adverse effects. New Zealand Medical Journal. 2010;123(1317). X-2, X-3, X-4.
1752 Raphael J, et al. Cancer Pain: Part 2: Physical, Interventional and Complimentary Therapies; Management in the Community; Acute, Treatment-Related and Complex Cancer Pain: A Perspective from the British Pain Society. Endorsed by the UK Association of Palliative Medicine and the Royal College of General Practitioners. Pain Medicine. 2010;11(6):872-896. X-1, X-2, X-3, X-4. [pmid: 20456069].
1753 Donders G, et al. Individualized decreasing-dose maintenance fluconazole regimen for recurrent vulvovaginal candidiasis (ReCiDiF trial). American Journal of Obstetrics and Gynecology. 2008;199(6). X-2, X-3, X-4.
1754 Bajaj P, Nanda R, Goyal PK. Superior hypogastric plexus block for pelvic cancer pain. Journal of Anaesthesiology Clinical Pharmacology. 2003;19(2):161-164. X-2, X-3, X-4.
1755 Alvarez DJ, Rockwell PG. Trigger points: Diagnosis and management. American Family Physician. 2002;65(4):653-660. X-1, X-2, X-3, X-4, X-5. [pmid: 11871683].
1756 Richlin SS, Rock JA. Ovarian remnant syndrome. Gynaecological Endoscopy. 2001;10(2):111-117. X-1, X-2, X-3, X-4.
1757 Kwan KS, Roberts LJ, Swalm DM. Sexual dysfunction and chronic pain: the role of psychological variables and impact on quality of life. Eur J Pain. 2005;9(6):643-52. X-2, X-3, X-4, X-5. [pmid: 16246817].
1758 Thornton JG, et al. The relationship between laparoscopic disease, pelvic pain and infertility; an unbiased assessment. Eur J Obstet Gynecol Reprod Biol. 1997;74(1):57-62. X-4. [pmid: 9243204].
1759 Peters AA, et al. A randomized clinical trial on the benefit of adhesiolysis in patients with intraperitoneal adhesions and chronic pelvic pain. Br J Obstet Gynaecol. 1992;99(1):59-62. X-3. [pmid: 1547175].
1760 Zhang Z. Patient-assisted Laparoscopic Pain Mapping in Women with Chronic Pelvic Pain. XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009). Cape Town International Convention Centre, Cape Town. 4-9 Oct 2009. X-1.
1761 Poli-Neto O, et al. Nitric oxide blood levels in women with chronic pelvic pain: a pilot study. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-3.
1762 Poli-Neto O, et al. Prevalence of chronic pelvic pain in women from Ribeirao Preto - Brazil. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-4.
1763 Montenegro M, et al. Association between tenderness of pelvic muscles and dyspareunia in women with chronic pelvic pain. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-2, X-3.
1764 Montenegro M, et al. Thiele massage as possible therapeutic intervention for women with chronic pelvic pain caused by tenderness of the levator ani muscle. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-1.
1765 Gomide L, et al. Evaluation of respiratory muscles strength in women with chronic pelvic pain. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-4.
1766 Romao A, et al. The Influence of Depression and of Pain Intensity on the Sexual Function of Women with Chronic Pelvic Pain. 6th Congress of the European Federation of the Chapters of the International Association for the Study of Pain (EFIC 2009), AIP Congressos Lisboa Congress Centre. Lisbon (Portugal). 9-12 Sep 2009. X-1.
1767 Romanini M. Transvaginal Sonographic Mapping of Pelvic Adhesions in Women with Chronic Pelvic Pain. 17th World Congress on Ultrasound in Obstetrics and Gynecology. Florence (Italy). 7-11 Oct 2007. X-1.
1768 Malt U, et al. Posture, Movement Patterns, and Body Awareness in Women with Chronic Pelvic Pain. 53rd Annual Meeting of the Academy of Psychosomatic Medicine (APM 2006). Loews Ventana Canyon Resort, Tucson, Arizona (USA). 15-19 Nov 2006. X-3.
1769 Latthe PM, et al. Factors Predisposing Women to Chronic Pelvic Pain: Systematic Review. 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6-9 Sep 2006. X-1, X-4.
1770 Haggerty C, Schulz R, Ness R. Lower quality of life among women with chronic pelvic pain following pelvic inflammatory disease. International Society for Sexually Transmitted Diseases Research 15th Annual Meeting. Ottawa (Canada). 27-31 Jul 2003. (World Meeting Number 000 6948). X-3, X-4.
1771 Rae T, et al. Ultrasound in the evaluation of chronic pelvic pain in women after hysterectomy and bilateral salpingo-oophorectomy. Twenty-Fifth Annual Meeting of the British Medical Ultrasound Society. Eastbourne (UK). 7-9 Dec 1993. (World Meeting Number 934 5039). X-1.
1772 Heim C, et al. Psychoendocrinology of sexual abuse in women with chronic pelvic pain. 1995 Annual Meeting of the American Psychiatric Association. Miami, FL (USA). 20-25 May 1995. (World Meeting Number 952 0358). X-3.
1773 McDonnell KA, Curbow BA. Quality of life among women with chronic pelvic pain. 106th American Psychological Association (APA) Annual Meeting. San Francisco, CA (USA). 14-18 Aug 1998. (World Meeting Number 983 0117). X-1.
1774 Graziottin A. Menopause and sexuality: Key issues in premature menopause and beyond. 2010:254-261. X-1, X-2, X-3, X-4.
1775 Villavicencio JL. Pelvic venous disorders: The desperate plea of women with the nutcracker syndrome. Phlebolymphology. 2010;17(1):39-40. X-1.
1776 Ouyang A, Wrzos HF. Contribution of gender to pathophysiology and clinical presentation of IBS: Should management be different in women?. American Journal of Gastroenterology. 2006;101(SUPPL. 3). X-1, X-2, X-3, X-4.
1777 Tzafettas J. Painful menstruation. Pediatric Endocrinology Reviews. 2006;3(SUPPL. 1):160-163. X-1, X-2, X-3, X-4. [pmid: 16641851].
1778 Klauser A, et al. Clinical diagnosis and imaging of sacroiliitis, Innsbruck, Austria, October 9, 2003. Journal of Rheumatology. 2004;31(10):2041-2047. X-1, X-2, X-3, X-4. [pmid: 15468373].
1779 Burkman RT. Chronic Pelvic Pain of Bladder Origin: Epidemiology, Pathogenesis and Quality of Life. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 2004;49(3 SUPPL):225-229. X-1, X-2, X-3, X-4. [pmid: 15088860].
1780 Sand PK. Chronic Pain Syndromes of Gynecologic Origin. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 2004;49(3 SUPPL):230-234. X-1, X-2, X-3, X-4. [pmid: 15088861].
1781 Mishell DR Jr. Chronic Pelvic Pain in Women: Focus on the Bladder. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 2004;49(3 SUPPL):223-224. X-1, X-2, X-3, X-4. [pmid: 15088859].
1782 Chancellor MB, Yoshimura N. Treatment of interstitial cystitis. Urology. 2004;63(3 SUPPL. 1):85-92. X-1, X-2, X-3, X-4. [pmid: 15013658].
1783 Milingos S, et al. Laparoscopic management of patients with endometriosis and chronic pelvic pain. 2003:269-273. X-1, X-2, X-3, X-4.
1784 Chapron C. Chronic pelvic pain and endometriosis. Douleur et endométriose profonde. 2003;32(8 II). X-1, X-2, X-3, X-4.
1785 Audebert A. Pathophysiology, symptomatology and therapeutic management of stage III and IV endometriosis. Endométriose stade III et IV: Implications physiopathologiques, cliniques et thérapeutiques. 2003;32(8 II). X-1, X-2, X-3, X-4.
1786 Valle RF, Sciarra JJ. Endometriosis: Treatment strategies. 2003:229-239. X-1, X-2, X-3, X-4.
1787 Potts JM. Alternative approaches to the management of prostatitis: Biofeedback, progressive relaxation and the concept of functional somatic syndromes. European Urology, Supplement. 2003;2(2):34-37. X-1, X-2, X-3, X-4.
1788 Rice VM. Conventional medical therapies for endometriosis. 2002:343-352. X-1, X-2, X-3, X-4.
1789 Fazleabas AT, et al. A modified baboon model for endometriosis. 2002:308-317. X-1, X-2, X-3, X-4.
1790 Myers DL, Aguilar VC. Gynecologic manifestations of interstitial cystitis. Clinical Obstetrics and Gynecology. 2002;45(1):233-241. X-1, X-2, X-3, X-4. [pmid: 11862075].
1791 Duffy S. Chronic pelvic pain: defining the scope of the problem. International Journal of Gynecology and Obstetrics. 2001;74(SUPPL. 1). X-1, X-2, X-3, X-4.
1792 Walker JJ. Focus for the future: Tackling the ‘pelvic pain’ problem in gynecologic practice - An interactive session. International Journal of Gynecology and Obstetrics. 2001;74(SUPPL. 1). X-2, X-3, X-4.
1793 Guaschino S, De Seta F. Update on Chlamydia trachomatis. 2000:293-300. X-1, X-2, X-3, X-4.
1794 Mayer EA, et al. Gender-related differences in functional gastrointestinal disorders. Alimentary Pharmacology and Therapeutics. Supplement. 1999;13(2):65-69. X-1, X-2, X-3, X-4. [pmid: 10429743].
1795 Walker JJ, Irvine G. How should we approach the management of pelvic pain?. Gynecologic and Obstetric Investigation. 1998;45(SUPPL. 1):6-11. X-1, X-2, X-3. [pmid: 9628519].
1796 Riedel HH, Emmert C. The impact of pelviscopy for gynecological-surgical differential diagnosis between endometriosis and chronic appendicitis. Die Pelviskopie im Rahmen gynakologisch-chirurgischer Differentialdiagnostik. 1998;123(SUPPL. 4):50-52. X-1, X-2, X-3, X-4.
1797 Hanna L, Bartnof HS. Selected highlights from the National Conference on Women & HIV. Pasadena, CA. May 4-8, 1997. BETA bulletin of experimental treatments for AIDS : a publication of the San Francisco AIDS foundation. 1997:38-45. X-1, X-2, X-3, X-4.
1798 Munday PE. Clinical aspects of pelvic inflammatory disease. Journal of the British Fertility Society. 1997;2(2):121-126. X-1, X-2, X-3, X-4.
1799 Henry-Suchet J, Askienazy-Elbhar M, Orfila J. Clinical consequences of immune response to CT upper genital tract infection in women. Infectious Diseases in Obstetrics and Gynecology. 1996;4(3):171-175. X-1, X-2, X-3, X-4. [pmid: 18476090].
1800 Unger JB, Meeks GR, Richardson DA. Hysterectomy after endometrial ablation. American Journal of Obstetrics and Gynecology. 1996;175(6):1432-1437. X-3, X-4. [pmid: 8987921].
1801 McDonald JS. Pelvic pain. Journal of Back and Musculoskeletal Rehabilitation. 1996;7(2):119-133. X-1, X-2, X-3, X-4.
1802 Reiter RC, et al. Somatization and causal pain attributions in women who have undergone hysterectomy for chronic pelvic pain. Women's Health Issues. 1995;5(4):239. X-4.
1803 Yonkers KA, Chantilis SJ. Recognition of depression in obstetric/gynecology practices. American Journal of Obstetrics and Gynecology. 1995;173(2):632-638. X-1, X-2, X-3, X-4. [pmid: 7645645].
1804 Damario MA, Rock JA. Pain recurrence: A quality of life issue in endometriosis. International Journal of Gynecology and Obstetrics. 1995;50(SUPPL. 1). X-1, X-2, X-3, X-4.
1805 Webster DC. Reframing women's health: Tension and paradox in framing interstitial cystitis. Journal of Women's Health. 1993;2(1):81-84. X-1, X-2, X-3, X-4.
1806 Ault KA, Faro S. Pelvic inflammatory disease: Current diagnostic criteria and treatment guidelines. Postgraduate Medicine. 1993;93(2):85-86+89. X-1, X-2, X-3, X-4. [pmid: 8433960].
1807 Reiter CR. Occult somatic pathology in women with chronic pelvic pain. Clinical Obstetrics and Gynecology. 1990;33(1):154-160. X-1, X-2, X-3, X-4. [pmid: 2178832].
1808 Reiter RC. A profile of women with chronic pelvic pain. Clinical Obstetrics and Gynecology. 1990;33(1):130-136. X-1, X-2, X-3, X-4. [pmid: 2178830].
1809 Fillingim RB, Maixner W. Sex related factors in temporomandibular disorders. Sex, Gender and Pain: Progress in Pain Research and Management. Fillingim R, editor. 2000. IASP Press. Seattle. X-1, X-2, X-3, X-4.
1810 C DC, M P, M L. Chronic pelvic pain, in Women's health: Contemporary international perspectives. 2000. British Psychological Society Books. London. X-1, X-2, X-3.
1811 Vercellini P, et al. Laparoscopy in the diagnosis of chronic pelvic pain in adolescent women. J Reprod Med. 1989;34(10):827-30. X-3. [pmid: 2529373].
1812 Thomson AJ, et al. The use of botulinum toxin type A (BOTOX) as treatment for intractable chronic pelvic pain associated with spasm of the levator ani muscles. BJOG. 2005;112(2):247-9. X-3. [pmid: 15663593].
1813 Hammoud A, et al. Adhesions in patients with chronic pelvic pain: a role for adhesiolysis?. Fertil Steril. 2004;82(6):1483-91. X-1, X-2, X-3, X-4. [pmid: 15589847].
1814 Sorenson SC, et al. Knee extensor dynamics in the volleyball approach jump: the influence of patellar tendinopathy. Journal of Orthopaedic & Sports Physical Therapy. 2010;40(9):568-576. X-2, X-3, X-4. [pmid: 20508329].
1815 Alhamdan D, et al. Mirena intra-uterine system: does it improve long term symptoms in women with chronic pelvic pain and/or endometriosis after laparoscopy? A multicentre randomized controlled trial. Rev Recent Clin Trials. 2010;5(3):143-6. X-1, X-2, X-3, X-4, X-5. [pmid: 20482495].
1816 Asciutto G, et al. Pelvic vein incompetence influences pain levels in patients with lower limb varicosity. Phlebology. 2010;25(4):179-83. X-2, X-3, X-4. [pmid: 20656955].
1817 Demircay E, et al. Radiofrequency thermocoagulation of ganglion impar in the management of coccydynia: preliminary results. Turk Neurosurg. 2010;20(3):328-33. X-2, X-3, X-4. [pmid: 20669105].
1818 Foley C, Patki P, Boustead G. Unrecognized bladder perforation with midurethral slings. BJU Int. 2010;106(10):1514-8. X-2, X-3, X-4. [pmid: 20518762].
1819 Jarrell J. Demonstration of cutaneous allodynia in association with chronic pelvic pain. J Vis Exp. 2009;(28). X-1, X-2, X-3.
1820 Liang CZ, et al. Prevalence of premature ejaculation and its correlation with chronic prostatitis in Chinese men. Urology. 2010;76(4):962-6. X-2, X-3, X-4. [pmid: 20381832].
1821 Magri V, et al. Use of the UPOINT chronic prostatitis/chronic pelvic pain syndrome classification in European patient cohorts: sexual function domain improves correlations. J Urol. 2010;184(6):2339-45. X-2, X-3, X-4, X-5. [pmid: 20952019].
1822 Protopapas A, et al. Immunohistochemical expression of matrix metalloproteinases, their tissue inhibitors, and cathepsin-D in ovarian endometriosis: correlation with severity of disease. Fertil Steril. 2010;94(6):2470-2. X-4. [pmid: 20385381].
1823 Tu CH, et al. Brain morphological changes associated with cyclic menstrual pain. Pain. 2010;150(3):462-8. X-2, X-3, X-4. [pmid: 20705214].
1824 Calabrò RS, et al. Misdiagnosed chronic pelvic pain: Pudendal neuralgia responding to a novel use of palmitoylethanolamide. Pain Medicine. 2010;11(5):781-784. X-2, X-3, X-4. [pmid: 20345619].
1825 Kumar A, Gupta V, Maurya A. Mental health and quality of life of chronic pelvic pain and endometriosis patients. Journal of Projective Psychology & Mental Health. 2010;17(2):153-157. X-2, X-3, X-4, X-5.
1826 Leithner-Dziubas K, et al. Mentalisierungsfähigkeit und bindung bei patientinnen mit chronischen unterbauchschmerzen: Eine pilotstudie. Mentalization and bonding in chronic pelvic pain patients: A pilot study. Zeitschrift für Psychosomatische Medizin und Psychotherapie. 2010;56(2):179-190. X-3, X-4.
1827 Seng JS. Posttraumatic oxytocin dysregulation: Is it a link among posttraumatic self disorders, posttraumatic stress disorder, and pelvic visceral dysregulation conditions in women?. Journal of Trauma & Dissociation. 2010;11(4):387-406. X-1, X-2, X-3, X-4. [pmid: 20938865].
1828 Zhao FL, et al. Health-related quality of life in Chinese patients with chronic prostatitis/chronic pelvic pain syndrome. Quality of Life Research: An International Journal of Quality of Life Aspects of Treatment, Care & Rehabilitation. 2010;19(9):1273-1283. X-2, X-3, X-4.
1829 Learman LA, et al. Symptom resolution after hysterectomy and alternative treatments for chronic pelvic pain: does depression make a difference?. Am J Obstet Gynecol. 2011;204(3):269 e1-9. X-2, X-3. [pmid: 21376168].
1830 Hartmann KE, et al. Quality of life and sexual function after hysterectomy in women with preoperative pain and depression. Obstet Gynecol. 2004;104(4):701-9. X-2, X-3. [pmid: 15458889].
1831 Kuppermann M, et al. Effect of noncancerous pelvic problems on health-related quality of life and sexual functioning. Obstet Gynecol. 2007;110(3):633-42. X-2, X-3, X-4, X-5. [pmid: 17766611].
1832 Atalar B, et al. Adult langerhans cell histiocytosis of bones : a rare cancer network study. Acta Orthop Belg. 2010;76(5):663-8. X-1, X-2, X-3, X-4. [pmid: 21138223].
1833 Balke M, et al. Bisphosphonate treatment of aggressive primary, recurrent and metastatic Giant Cell Tumour of Bone. BMC Cancer. 2010;10:462. X-2, X-3, X-4. [pmid: 20799989].
1834 Bayoglu Tekin Y, et al. Postoperative medical treatment of chronic pelvic pain related to severe endometriosis: levonorgestrel-releasing intrauterine system versus gonadotropin-releasing hormone analogue. Fertil Steril. 2011;95(2):492-6. X-3. [pmid: 20883991].
1835 Cambitzi J. Chronic pelvic pain: causes, mechanisms and effects. Nurs Stand. 2011;25(20):35-8. X-1, X-2, X-3. [pmid: 21329169].
1836 Choung RS, et al. Irritable bowel syndrome and chronic pelvic pain: a population-based study. J Clin Gastroenterol. 2010;44(10):696-701. X-2, X-3. [pmid: 20375730].
1837 Coccia ME, Rizzello F, Gianfranco S. Does controlled ovarian hyperstimulation in women with a history of endometriosis influence recurrence rate?. J Womens Health (Larchmt). 2010;19(11):2063-9. X-2, X-3, X-4. [pmid: 20831441].
1838 Dickstein R, Uberoi J, Munarriz R. Severe, disabling, and/or chronic penile pain associated with Peyronie disease: management with subcutaneous steroid injection. J Androl. 2010;31(5):445-9. X-2, X-3, X-4. [pmid: 19684339].
1839 Dozois EJ, et al. High sacrectomy for locally recurrent rectal cancer: Can long-term survival be achieved?. J Surg Oncol. 2011;103(2):105-9. X-2, X-3, X-4. [pmid: 21259242].
1840 Eccles R, Holbrook A, Jawad M. A double-blind, randomised, crossover study of two doses of a single-tablet combination of ibuprofen/paracetamol and placebo for primary dysmenorrhoea. Curr Med Res Opin. 2010;26(11):2689-99. X-2, X-3, X-4. [pmid: 20942614].
1841 Furstenberg A, Buscombe J, Davenport A. Overestimation of lumbar spine calcium with dual energy X-ray absorptiometry scanning due to the prescription of lanthanum carbonate in patients with chronic kidney disease. Am J Nephrol. 2010;32(5):425-31. X-2, X-3, X-4. [pmid: 20861616].
1842 Garcia-Perez H, et al. Pelvic pain and associated characteristics among women in northern Mexico. Int Perspect Sex Reprod Health. 2010;36(2):90-8. X-4. [pmid: 20663745].
1843 Gottsch HP, Yang CC, Berger RE. A pilot study of botulinum toxin A for male chronic pelvic pain syndrome. Scand J Urol Nephrol. 2011;45(1):72-6. X-2, X-3, X-4. [pmid: 21062115].
1844 Govaert B, et al. Sacral neuromodulation for the treatment of chronic functional anorectal pain: a single center experience. Pain Pract. 2010;10(1):49-53. X-2, X-3, X-4. [pmid: 19735362].
1845 Guo H, et al. Heat-shock protein 70 expression in the seminal plasma of patients with chronic bacterial prostatitis and chronic prostatitis/chronic pelvic pain syndrome. Prostate Cancer Prostatic Dis. 2010;13(4):338-42. X-2, X-3, X-4. [pmid: 20585345].
1846 Liu X, Nie J, Guo SW. Elevated immunoreactivity to tissue factor and its association with dysmenorrhea severity and the amount of menses in adenomyosis. Hum Reprod. 2011;26(2):337-45. X-2, X-3, X-4. [pmid: 21115504].
1847 Montenegro ML, et al. Thiele massage as a therapeutic option for women with chronic pelvic pain caused by tenderness of pelvic floor muscles. J Eval Clin Pract. 2010;16(5):981-2. X-3. [pmid: 20590980].
1848 Neziri AY, et al. Generalized expansion of nociceptive reflex receptive fields in chronic pain patients. Pain. 2010;151(3):798-805. X-3, X-4. [pmid: 20926191].
1849 Patrelli TS, et al. CA 125 serum values in surgically treated endometriosis patients and its relationships with anatomic sites of endometriosis and pregnancy rate. Fertil Steril. 2011;95(1):393-6. X-2, X-3, X-4. [pmid: 20934691].
1850 Peters KM, et al. Chronic pudendal neuromodulation: expanding available treatment options for refractory urologic symptoms. Neurourol Urodyn. 2010;29(7):1267-71. X-3, X-2, X-4. [pmid: 19787710].
1851 Possover M, Schneider T, Henle KP. Laparoscopic therapy for endometriosis and vascular entrapment of sacral plexus. Fertil Steril. 2011;95(2):756-8. X-2, X-4. [pmid: 20869701].
1852 Putnis SE, et al. Open reduction and internal fixation of a traumatic diastasis of the pubic symphysis: one-year radiological and functional outcomes. J Bone Joint Surg Br. 2011;93(1):78-84. X-2, X-3, X-4. [pmid: 21196548].
1853 Rudick CN, et al. Uropathogenic Escherichia coli induces chronic pelvic pain. Infect Immun. 2011;79(2):628-35. X-3, X-4. [pmid: 21078846].
1854 Sharma D, et al. Diagnostic laparoscopy in chronic pelvic pain. Arch Gynecol Obstet. 2011;283(2):295-7. X-3, X-4. [pmid: 20072784].
1855 Somprasit C, et al. Transvaginal color Doppler study of uterine artery: is there a role in chronic pelvic pain?. J Obstet Gynaecol Res. 2010;36(6):1174-8. X-3, X-4. [pmid: 20722981].
1856 Sone M, et al. Phase I/II multiinstitutional study of uterine artery embolization with gelatin sponge for symptomatic uterine leiomyomata: Japan Interventional Radiology in Oncology Study Group study. J Vasc Interv Radiol. 2010;21(11):1665-71. X-2, X-3, X-4. [pmid: 20884240].
1857 Tacu C, et al. Differentiation of patients with chronic lombosciatica due to disc hernia using gait analysis techniques. Rev Med Chir Soc Med Nat Iasi. 2010;114(3):694-9. X-2, X-3, X-4. [pmid: 21235116].
1858 Van Kerrebroeck PE. Advances in the role of sacral nerve neuromodulation in lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Suppl 2. 2010;21:S467-74. X-1, X-2, X-3, X-4.
1859 Wegrzyn J, et al. Cementless total hip arthroplasty in Paget's disease of bone: a retrospective review. Int Orthop. 2010;34(8):1103-9. X-1, X-2, X-3, X-4. [pmid: 19669762].
1860 Wei X, et al. Detection and quantitation of soluble B7-H3 in expressed prostatic secretions: a novel marker in patients with chronic prostatitis. J Urol. 2011;185(2):532-7. X-2, X-3, X-4. [pmid: 21168885].
1861 Zmora O, et al. Multimedia manuscript. Laparoscopic rectopexy with posterior mesh fixation. Surg Endosc. 2011;25(1):313-4. X-2, X-3, X-4. [pmid: 20567848].
1862 Figuers CC, et al. Physical therapist interventions for voiding dysfunction and pelvic pain: a retrospective case series. Journal of Women's Health Physical Therapy. 2010;34(2):40-44. X-3.
1863 Neville CE, et al. Physical examination findings by physical therapists compared with physicians of musculoskeletal factors in women with chronic pelvic pain. Journal of Women's Health Physical Therapy. 2010;34(3):73-80. X-4.
1864 Peterson ML, et al. A comparison of posture and sit-to-stand biomechanics of pregnant women in the third trimester with and without a maternity support: a pilot study. Journal of Women's Health Physical Therapy. 2010;34(1):3-9. X-2, X-3, X-4.
1865 Sendtner E, et al. Stem torsion in total hip replacement: CT measurements in 60 patients. Acta Orthopaedica. 2010;81(5):579-582. X-2, X-3, X-4. [pmid: 20919811].
1866 Steinhilber B, et al. Reproducibility of concentric isokinetic and isometric strength measurements at the hip in patients with hip osteoarthritis: a preliminary study. Isokinetics & Exercise Science. 2011;19(1):39-46. X-2, X-3, X-4.
1867 Ziadé N, Jougla E, Coste J. Population-Level Impact of Osteoporotic Fractures on Mortality and Trends Over Time: A Nationwide Analysis of Vital Statistics for France, 1968-2004. American Journal of Epidemiology. 2010;172(8):942-951. X-1, X-2, X-3, X-4. [pmid: 20705803].
1868 ACOG releases a report on chronic pelvic pain. American Family Physician. 1996;54(5):1793-1794. X-1, X-2, X-3. [pmid: 8857797].
1869 Abejon D, et al. Direct sacral root stimulation: Another possibility in chronic pelvic pain management. Techniques in Regional Anesthesia and Pain Management. 2010;14(3):120-127. X-2, X-3, X-4.
1870 Ablove T. Post void dribbling: Incidence and risk factors. Neurourology and Urodynamics. 2010;29(3):432-436. X-2, X-3, X-4. [pmid: 19634165].
1871 Alexander RB. Prostatitis: Clinical phenotyping of patients with pelvic pain. Nature Reviews Urology. 2009;6(10):531-532. X-1, X-2, X-3, X-4.
1872 Alexander RB, et al. The National Institutes of Health chronic prostatitis symptom index: Development and validation of a new outcome measure. Journal of Urology. 1999;162(2):369-375. X-2, X-3, X-4. [pmid: 10411041].
1873 Alhadad A, et al. Iliocaval vein stenting: Long term survey of postthrombotic symptoms and working capacity. Journal of Thrombosis and Thrombolysis. 2011;31(2):211-216. X-2, X-3, X-4. [pmid: 20640483].
1874 Almeida OD Jr, Val-Gallas JM. Conscious pain mapping of the appendix with microlaparoscopy for the evaluation of women with chronic pelvic pain. Middle East Fertility Society Journal. 1999;4(3):233-236. X-3, X-4.
1875 Amin AF, et al. Endoscopic management of chronic pelvic pain. Middle East Fertility Society Journal. 2000;5(1):57-61. X-3.
1876 Anderson RU, et al. 6-Day intensive treatment protocol for refractory chronic prostatitis/chronic pelvic pain syndrome using myofascial release and paradoxical relaxation training. Journal of Urology. 2011;185(4):1294-1299. X-2, X-3, X-4. [pmid: 21334027].
1877 Angioli R, et al. Tension-free vaginal tape versus transobturator suburethral tape: Five-year follow-up results of a prospective, randomised trial. European Urology. 2010;58(5):671-677. X-2, X-3, X-4. [pmid: 20709444].
1878 Antolak SJ Jr, Antolak CM. Failed sacral neuromodulation: Simple tests demonstrate pudendal neuropathy. Journal of Pelvic Medicine and Surgery. 2006;12(1):35-39. X-3, X-4.
1879 Bak AP, et al. Chronic pelvic pain and neurotic behavior. Journal of Psychosomatic Obstetrics and Gynaecology. 1990;11(1):29-35. X-4.
1880 Ballard K, Lowton K, Wright J. Balancing the risks and benefits of different diagnostic interventions for chronic pelvic pain. Fertility and Sterility. 2006;86(5). X-1, X-2, X-3.
1881 Balleyguier C, et al. Ureteral endometriosis: The role of magnetic resonance imaging. Journal of the American Association of Gynecologic Laparoscopists. 2004;11(4):530-536. X-3, X-4. [pmid: 15701198].
1882 Banerjee S, et al. Deep and superficial endometriotic disease: The response to radical laparoscopic excision in the treatment of chronic pelvic pain. Gynecological Surgery. 2006;3(3):199-205. X-3, X-4, X-5.
1883 Barisic D, et al. The diagnostic accuracy of a 1.2-mm minilaparoscope. Gynaecological Endoscopy. 1996;5(5):283-286. X-3, X-4.
1884 Barrenetxea G, et al. Cervical conization results and complications. A twelve-year experience. Cervix and the Lower Female Genital Tract. 1992;10(1):39-43. X-2, X-3, X-4.
1885 Beales DJ, et al. Motor control patterns during an active straight leg raise in chronic pelvic girdle pain subjects. Spine. 2009;34(9):861-870. X-3, X-4. [pmid: 19531994].
1886 Bedaiwy MA, Liu J. Pathophysiology, diagnosis, and surgical management of endometriosis: A chronic disease. Sexuality, Reproduction and Menopause. 2010;8(3):4-8. X-1, X-2, X-3.
1887 Begum A, et al. Residual ovary syndrome. Bangladesh Journal of Obstetrics and Gynecology. 1999;14(1):13-17. X-3, X-4.
1888 Bekker F, Peters L, Bayer-Rots M. Chronic pelvic pain patients and conflicts in gender identity. Journal of Psychosomatic Obstetrics and Gynaecology. 1990;11(1):19-28. X-4.
1889 Bellabarba C, et al. Midline sagittal sacral fractures in anterior-posterior compression pelvic ring injuries. Journal of Orthopaedic Trauma. 2003;17(1):32-37. X-2, X-3, X-4. [pmid: 12499965].
1890 Bemelmans BLH, Mundy AR, Craggs MD. Neuromodulation by implant for treating lower urinary tract symptoms and dysfunction. European Urology. 1999;36(2):81-91. X-1, X-2, X-3, X-4. [pmid: 10420026].
1891 Boneva RS, et al. Gynecological history in chronic fatigue syndrome: A population-based case-control study. Journal of Women's Health. 2011;20(1):21-28. X-3, X-4.
1892 Boomsma JHB, et al. Phlebography and embolization in women with pelvic vein insufficiency. MedicaMundi. 1998;42(2):22-29. X-3, X-4.
1893 Brown J, et al. Combination of gemcitabine and cisplatin is highly active in women with endometrial carcinoma. Cancer. 2010;116(21):4973-4979. X-2, X-3, X-4. [pmid: 20665499].
1894 Caldwell J, Hart-Johnson T, Green CR. Body Mass Index and Quality of Life: Examining Blacks and Whites With Chronic Pain. Journal of Pain. 2009;10(1):60-67. X-4. [pmid: 18799358].
1895 Candiani M, et al. Laparoscopic management of pelvic pain and adnexal masses in adolescent and paediatric patients. Italian Journal of Gynaecology and Obstetrics. 1997;9(2):82-86. X-2, X-3, X-4.
1896 Chaitow L. Chronic pelvic pain: Pelvic floor problems, sacro-iliac dysfunction and the trigger point connection. Journal of Bodywork and Movement Therapies. 2007;11(4):327-339. X-1, X-2, X-3.
1897 Chawla SCS. Treatment of endometriosis and chronic pelvic pain with letrozole and norethindrone acetate. Medical Journal Armed Forces India. 2010;66(3):213-215. X-3.
1898 Chen L, et al. A survey of selected physician views on acupuncture in pain management. Pain Medicine. 2010;11(4):530-534. X-2, X-3, X-4. [pmid: 20202145].
1899 Chiou RK. Editorial Comment. Journal of Urology. 2006;176(4):1538-1539. X-1, X-2, X-3 ,X-4.
1900 Choung RS, Locke GR. Epidemiology of IBS. Gastroenterology Clinics of North America. 2011;40(1):1-10. X-1, X-2, X-3, X-4. [pmid: 21333897].
1901 Cicchiello LA, Hamper UM, Scoutt LM. Ultrasound Evaluation of Gynecologic Causes of Pelvic Pain. Obstetrics and Gynecology Clinics of North America. 2011;38(1):85-114. X-1, X-2, X-3, X-4. [pmid: 21419329].
1902 Clemens JQ, et al. Prevalence of interstitial cystitis symptoms in a managed care population. Journal of Urology. 2005;174(2):576-580. X-2, X-3, X-4. [pmid: 16006901].
1903 Clemens JQ, et al. Incidence and clinical characteristics of National Institutes Of Health type III prostatitis in the community. Journal of Urology. 2005;174(6):2319-2322. X-2, X-3, X-4. [pmid: 16280832].
1904 Colombo R, et al. Thermo-chemotherapy and electromotive drug administration of mitomycin C in superficial bladder cancer eradication: A pilot study on marker lesion. European Urology. 2001;39(1):95-100. X-2, X-3, X-4. [pmid: 11173946].
1905 Currie SR, et al. Cognitive-behavioral treatment of insomnia secondary to chronic pain. Journal of Consulting and Clinical Psychology. 2000;68(3):407-416. X-4. [pmid: 10883557].
1906 Damario MA, Horowitz IR, Rock JA. The role of uterosacral ligament resection in conservative operations for recurrent endometriosis. Journal of Gynecologic Surgery. 1994;10(2):57-61. X-2, X-3, X-4.
1907 Damiano R, et al. Prevention of recurrent urinary tract infections by intravesical administration of hyaluronic acid and chondroitin sulphate: A placebo-controlled randomised trial. European Urology. 2011;59(4):645-651. X-2, X-3, X-4. [pmid: 21272992].
1908 Daniels J, et al. Laparoscopic uterine nerve ablation: A survey of gynaecological practice in the UK. Gynaecological Endoscopy. 2000;9(3):157-159. X-2, X-3, X-4.
1909 Daniilidis A, et al. Diagnostic laparoscopy, infertility, and endometriosis - 5 Years experience. Gynecological Surgery. 2008;5(3):231-234. X-4.
1910 Darwish AMM, Hassanin MS, Abou Sekkin IA. Epidemiology and risk factors associated with laparoscopically diagnosed typical and atypical endometriosis among Egyptian women. Middle East Fertility Society Journal. 2006;11(3):196-201. X-4.
1911 Davis SN, et al. Tenderness as Measured by Pressure Pain Thresholds Extends Beyond the Pelvis in Chronic Pelvic Pain Syndrome in Men. Journal of Sexual Medicine. 2011;8(1):232-239. X-2, X-3, X-4. [pmid: 20946176].
1912 De Rijk A, et al. Gender differences in return to work patterns among sickness absentees and their associations with health: A prospective cohort study in the Netherlands. International Journal of Rehabilitation Research. 2008;31(4):327-336. X-2, X-3, X-4. [pmid: 19008682].
1913 Demirel G, et al. Pain following spinal cord injury. Spinal Cord. 1998;36(1):25-28. X-2, X-3, X-4. [pmid: 9471134].
1914 Di Spiezio Sardo A, et al. Role of hysteroscopy in evaluating chronic pelvic pain. Fertility and Sterility. 2008;90(4):1191-1196. X-1, X-2, X-3. [pmid: 17880955].
1915 Diwadkar GB, Falcone T. Surgical management of pain and infertility secondary to endometriosis. Seminars in Reproductive Medicine. 2011;29(2):124-129. X-1, X-2, X-3. [pmid: 21437826].
1916 Donnez J, et al. Surgical management of endometriosis. Best Practice and Research in Clinical Obstetrics and Gynaecology. 2004;18(2):329-348. X-1, X-2, X-3.
1917 Donnez J, Squifflet J. Complications, pregnancy and recurrence in a prospective series of 500 patients operated on by the shaving technique for deep rectovaginal endometriotic nodules. Human Reproduction. 2010;25(8):1949-1958. X-4. [pmid: 20547557].
1918 Ejike CECC. Self-reported history of sexually transmitted infection and chronic prostatitis symptoms: A cross-sectional study of a Nigerian undergraduate population. International Journal of STD and AIDS. 2011;22(2):91-94. X-2, X-3, X-4. [pmid: 21427430].
1919 Elder JS. This Month in Pediatric Urology. Journal of Urology. 2007;178(4):1139-1140. X-1, X-2, X-3, X-4.
1920 El-Din Shawki H. The efficacy of laparoscopic uterosacral nerve ablation (LUNA) in the treatment of unexplained chronic pelvic pain: A randomized controlled trial. Gynecological Surgery. 2011;8(1):31-39. X-2, X-4. [pmid: 21461043].
1921 Engel J, Hoffmann SO. Cultural influences on chronic pelvic pain: A study on women in Brazil. European Journal of Pain. 1994;15(4):61-67. X-2, X-3, X-4.
1922 Erdem S, et al. Benign cystic lymphangioma presenting as a pelvic mass. Journal of Obstetrics and Gynaecology Research. 2006;32(6):628-630. X-3, X-4. [pmid: 17100830].
1923 Faouri M, Najdawi F. Prostatitis: Diagnostic Criteria and Classification. Journal of the Bahrain Medical Society. 2003;15(4):208-213. X-2, X-3, X-4.
1924 Fariello JY, Whitmore K. Sacral neuromodulation stimulation for IC/PBS, chronic pelvic pain, and sexual dysfunction. International Urogynecology Journal and Pelvic Floor Dysfunction. 2010;21(12):1553-1558. X-1, X-2, X-3.
1925 Farquhar CM, Hoghton GBS, Beard RW. Pelvic pain - Pelvic congestion or the irritable bowel syndrome?. European Journal of Obstetrics Gynecology and Reproductive Biology. 1990;37(1):71-75. X-3, X-4.
1926 Fasciani A, et al. Endometriosis Index: A software-derived score to predict the presence and severity of the disease. Journal of Endometriosis. 2010;2(2):79-86. X-4.
1927 Federici D, Muggiasca ML, Conti M. Diagnostic value of laparoscopic evaluation of women with chronic pelvic pain: Our experience and a review of the literature. Valeur diagnostique de l'exploration laparoscopique des femmes souffrant de douleurs pelviennes chroniques: experience personnelle et revue de la litterature. Acta Endoscopica. 1992;22(2):177-186. X-4.
1928 Felding C, Mikkelsen AL, Peen U. Laparoscopy and ultrasound in patients with chronic pelvic pain. Journal of Obstetrics and Gynaecology. 1990;10(5):419-422. X-4.
1929 Ferreira PH, Ferreira ML, Hodges PW. Changes in recruitment of the abdominal muscles in people with low back pain: Ultrasound measurement of muscle activity. Spine. 2005;29(22):2560-2566. X-2, X-3, X-4. [pmid: 15543074].
1930 Fowler J, et al. Computed tomographic appearances of the pelvis following hindquarter amputation. British Journal of Radiology. 1993;65(780):1093-1096. X-2, X-3, X-4. [pmid: 1286416].
1931 Friedman AL, Bloodgood B. “Something we'd rather not talk about”: Findings from CDC exploratory research on sexually transmitted disease communication with girls and women. Journal of Women's Health. 2010;19(10):1823-1831. X-2, X-3, X-4.
1932 Frohlich E, Shipton EA. Can the development of pain management units be justified in an emerging democracy?. South African Medical Journal. 2007;97(9):826-828. X-1, X-2, X-3, X-4. [pmid: 17987703].
1933 Ganeshan A, et al. Chronic pelvic pain due to pelvic congestion syndrome: The role of diagnostic and interventional radiology. CardioVascular and Interventional Radiology. 2007;30(6):1105-1111. X-1, X-2, X-3, X-4. [pmid: 17805925].
1934 Gbolade BA. Immediate insertion of the postabortion version of the GyneFix intrauterine implant system. Contemporary Reviews in Obstetrics and Gynaecology. 1999;11(1):29-33. X-1, X-2, X-3, X-4.
1935 Geller MA, et al. A phase II trial of carboplatin and docetaxel followed by radiotherapy given in a “Sandwich” method for stage III, IV, and recurrent endometrial cancer. Gynecologic Oncology. 2011;121(1):112-117. X-2, X-3, X-4. [pmid: 21239048].
1936 Gerlinger C, et al. Defining a minimal clinically important difference for endometriosis-associated pelvic pain measured on a visual analog scale: Analyses of two placebo-controlled, randomized trials. Health and Quality of Life Outcomes. 2010;8(138). X-2, X-3, X-4.
1937 Ghobish AA. Quantitative and qualitative assessment of flowmetrograms in patients with prostatodynia. European Urology. 2000;38(5):576-583. X-2, X-3, X-4. [pmid: 11096239].
1938 Goldstone A, Bushnell A. Does diagnosis change as a result of repeat renal colic computed tomography scan in patients with a history of kidney stones?. American Journal of Emergency Medicine. 2010;28(3):291-295. X-2, X-3, X-4. [pmid: 20223385].
1939 Gomel V. Chronic pelvic pain: A challenge. Journal of Minimally Invasive Gynecology. 2007;14(4):521-526. X-1, X-2, X-3, X-4. [pmid: 17630177].
1940 Gong Y, Tempfer CB. Regional lymphatic spread in women with pelvic endometriosis. Medical Hypotheses. 2011;76(4):560-563. X-1, X-2, X-3, X-4. [pmid: 21273006].
1941 Gustofson RL, et al. Endometriosis and the appendix: a case series and comprehensive review of the literature. Fertility and Sterility. 2006;86(2):298-303. X-4. [pmid: 16828481].
1942 Hackethal A, et al. Transvaginal NOTES with semi-rigid and rigid endoscopes that allow adjustable viewing angles. Archives of Gynecology and Obstetrics. 2011;283(1):131-132. X-1, X-2, X-3, X-4. [pmid: 20336463].
1943 Hadi N, Barazandeh F, Azad F. The prevalence of Chlamydia trachomatis infection in women attending health clinics in shiraz, Islamic Republic of Iran. International Journal of Fertility and Sterility. 2010;4(3):128-133. X-2, X-3, X-4.
1944 Hay D, et al. Laparoscopic oophorectomy for trapped ovary syndrome with occlusion of the infundibulopelvic ligament prior to division by the use of the Filshie clip. Gynaecological Endoscopy. 1996;5(4):241-243. X-3, X-4.
1945 Haylen BT, et al. An International Urogynecological Association (IUGA)/International Continence Society (ICS) joint report on the terminology for female pelvic floor dysfunction. International Urogynecology Journal and Pelvic Floor Dysfunction. 2010;21(1):5-26. X-1, X-2, X-3, X-4.
1946 Hebert KJ, et al. MRI appearance of chronic stress injury of the iliac crest apophysis in adolescent athletes. American Journal of Roentgenology. 2008;190(6):1487-1491. X-2, X-3, X-4. [pmid: 18492896].
1947 Heinig J, et al. Endosalpingiosis - An underestimated cause of chronic pelvic pain or an accidental finding? A retrospective study of 16 cases. European Journal of Obstetrics Gynecology and Reproductive Biology. 2002;103(1):75-78. X-3, X-4.
1948 Hobbs JT. The pelvic congestion syndrome. British Journal of Hospital Medicine. 1990;43(3):200-206. X-1, X-2, X-3. [pmid: 2180521].
1949 Hooten WM, et al. The effects of depression and smoking on pain severity and opioid use in patients with chronic pain. Pain. 2011;152(1):223-229. X-2, X-3, X-4. [pmid: 21126821].
1950 Howard FM. An evidence-based medicine approach to the treatment of endometriosis-associated chronic pelvic pain: Placebo-controlled studies. Journal of the American Association of Gynecologic Laparoscopists. 2000;7(4):477-488. X-1, X-3. [pmid: 11044498].
1951 Hudelist G, et al. Combination of transvaginal sonography and clinical examination for preoperative diagnosis of pelvic endometriosis. Human Reproduction. 2009;24(5):1018-1024. X-2, X-3, X-4. [pmid: 19202143].
1952 Hudelist G, et al. Can transvaginal sonography predict infiltration depth in patients with deep infiltrating endometriosis of the rectum?. Human Reproduction. 2009;24(5):1012-1017. X-2, X-3, X-4. [pmid: 19221097].
1953 Huntoon E, Huntoon M. Differential diagnosis of low back pain. Seminars in Pain Medicine. 2004;2(3):138-144. X-1, X-2, X-3, X-4.
1954 Jarrell J. Gynecological pain, endometriosis, visceral disease, and the viscero-somatic connection. Journal of Musculoskeletal Pain. 2008;16(1-2):21-27. X-4.
1955 Jean F, et al. Treatment of enterocele by abdominal colporectosacropexy - Efficacy on pelvic pressure. Colorectal Disease. 2002;4(5):321-325. X-2. [pmid: 12780575].
1956 Kamm MA. Chronic pelvic pain in women - Gastroenterological, gynaecological or psychological?. International Journal of Colorectal Disease. 1997;12(2):57-62. X-1, X-2, X-3, X-4. [pmid: 9189771].
1957 Kang BS, Shin HI, Bang MS. Effect of Repetitive Transcranial Magnetic Stimulation Over the Hand Motor Cortical Area on Central Pain After Spinal Cord Injury. Archives of Physical Medicine and Rehabilitation. 2009;90(10):1766-1771. X-3. [pmid: 19801069].
1958 Kavallaris A, et al. Management of symptomatic pelvic lymphocyst after radical pelvic or pelvic and paraaortic lymphadenectomy for cervical and endometrial cancer. Gynecological Surgery. 2009;6(4):345-349. X-2, X-3, X-4.
1959 Kennedy S. Should a diagnosis of endometriosis be sought in all symptomatic women?. Fertility and Sterility. 2006;86(5):1312-1313. X-1, X-3, X-4. [pmid: 17070188].
1960 Khan KS, et al. Laparoscopic uterosacral nerve ablation in chronic pelvic pain: An overview. Gynaecological Endoscopy. 1999;8(5):257-265. X-1, X-3.
1961 Kim TH, Kim HR, Myung SC. Detection of nanobacteria in patients with chronic prostatitis and vaginitis by reverse transcriptase polymerase chain reaction. Korean Journal of Urology. 2011;52(3):194-199. X-2, X-3, X-4. [pmid: 21461284].
1962 King PM, et al. Musculoskeletal factors in chronic pelvic pain. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):87-98. X-4.
1963 Krieger JN, et al. Chronic pelvic pains represent the most prominent urogenital symptoms of ‘chronic prostatitis’. Urology. 1996;48(5):715-722. X-2, X-3, X-4. [pmid: 8911515].
1964 Kurt A, et al. The relation between pelvic varicose veins, chronic pelvic pain, and lower extremity venous insufficiency in women. Phlebolymphology. 2008;15(2):61-67. X-4.
1965 Latthe P, et al. A randomised controlled trial to assess the efficacy of Laparoscopic Uterosacral Nerve Ablation (LUNA) in the treatment of chronic pelvic pain: The trial protocol [ISRCTN41196151]. BMC Women's Health. 2003;3(08). X-1.
1966 Lavano A, et al. Sacral nerve stimulation with percutaneous dorsal transforamenal approach in treatment of isolated pelvic pain syndromes. Neuromodulation. 2006;9(3):229-233. X-2, X-3, X-4. [pmid: 22151711].
1967 Leal Monedero J, et al. Embolization treatment of recurrent varices of pelvic origin. Phlebology. 2006;21(1):3-11. X-2, X-3, X-4.
1968 Letterie GS, et al. Laparoscopic appendectomy during operative gynaecological endoscopy. Gynaecological Endoscopy. 1993;2(1):39-40. X-1, X-3, X-4.
1969 Leveille SG, Cohen-Mansfield J, Guralnik JM. The impact of chronic musculoskeletal pain on exercise attitudes, self-efficacy, and physical activity. Journal of Aging and Physical Activity. 2003;11(2):275-283. X-2, X-3, X-4.
1970 Liang CZ, et al. The Prevalence of Prostatitis-Like Symptoms in China. Journal of Urology. 2009;182(2):558-563. X-2, X-3, X-4. [pmid: 19524948].
1971 Liang CZ, et al. An epidemiological study of patients with chronic prostatitis. BJU International. 2004;94(4):568-570. X-2, X-3, X-4. [pmid: 15329114].
1972 Lindheim SR. Chronic pelvic pain: Presumptive diagnosis and therapy using GnRH agonists. International Journal of Fertility and Women's Medicine. 1999;44(3):131-138. X-1, X-3, X-4.
1973 Ma H, et al. Clinical observation of three-dimensional conformal radiotherapy (3DCRT) with concurrent chemotherapy in treatment of recurrent cervical cancers. Chinese German Journal of Clinical Oncology. 2010;9(10):613-615. X-2, X-3, X-4.
1974 Maccioni M, et al. Immunological aspects of the prostate gland and related diseases. Current Immunology Reviews. 2010;6(4):287-298. X-1, X-2, X-3, X-4.
1975 Machan L, Martin ML. Ovarian vein embolization for pelvic congestion syndrome. Seminars in Interventional Radiology. 2000;17(3):277-284. X-1, X-2, X-3, X-4.
1976 Mahmood TA, Templeton A. Prevalence and genesis of endometriosis. Human Reproduction. 1991;6(4):544-549. X-2, X-3, X-4. [pmid: 1918305].
1977 Malnar G. Neural mechanisms of pain. International Journal of Fertility and Women's Medicine. 2004;49(4):155-158. X-1, X-2, X-3, X-4.
1978 March CM. Asherman's syndrome. Seminars in Reproductive Medicine. 2011;29(2):83-94. X-1, X-2, X-3, X-4. [pmid: 21437822].
1979 Margulies RU, et al. Complications requiring reoperation following vaginal mesh kit procedures for prolapse. American Journal of Obstetrics and Gynecology. 2008;199(6). X-2, X-3, X-4.
1980 Martinez DA, Rupert RL, Ndetan HT. A demographic and epidemiological study of a Mexican chiropractic college public clinic. Chiropractic and Osteopathy. 2009;17(4). X-2, X-3, X-4.
1981 McCarthy LH, et al. Chronic pain and obesity in elderly people: Results from the einstein aging study. Journal of the American Geriatrics Society. 2009;57(1):115-119. X-2, X-3, X-4, X-5. [pmid: 19054178].
1982 McClish DK, et al. Pain site frequency and location in sickle cell disease: The PiSCES project. Pain. 2009;145(1-2):246-251. X-2, X-3, X-4. [pmid: 19631468].
1983 McLucas B, Goodwin SC, Perrella R. Embolisation of myomata for pelvic haemorrhage: An alternative to hysterectomy. Minimally Invasive Therapy and Allied Technologies. 1998;7(3):261-265. X-2, X-3, X-4.
1984 Mereu L, et al. Laparoscopic management of ureteral endometriosis in case of moderate-severe hydroureteronephrosis. Fertility and Sterility. 2010;93(1):46-51. X-2, X-3, X-4. [pmid: 18990377].
1985 Mierzwa ML, et al. Interstitial brachytherapy for soft tissue sarcoma: A single institution experience. Brachytherapy. 2007;6(4):298-303. X-2, X-3, X-4. [pmid: 17959424].
1986 Najibi S, et al. Internal fixation of symphyseal disruption resulting from childbirth. Journal of Orthopaedic Trauma. 2010;24(12):732-739. X-3, X-4. [pmid: 21063219].
1987 Nazir FS, Lees KR, Bone I. Clinical features associated with medically unexplained stroke-like symptoms presenting to an acute stroke unit. European Journal of Neurology. 2005;12(2):81-85. X-2, X-3, X-4. [pmid: 15679694].
1988 Nicholson SC, Gillmer MDG. Hysterectomy following failed endometrial resection. Journal of Obstetrics and Gynaecology. 1997;17(1):71-75. X-3, X-4. [pmid: 15511776].
1989 Nickel JC, et al. Clinical evaluation of the man with chronic prostatitis/chronic pelvic pain syndrome. Urology. 2002;60(6 SUPPL. A):20-23. X-1, X-2, X-3, X-4. [pmid: 12521583].
1990 Obermair A, et al. Prospective, non-randomized phase 2 clinical trial of carboplatin plus paclitaxel with sequential radical pelvic radiotherapy for uterine papillary serous carcinoma. Gynecologic Oncology. 2011;120(2):179-184. X-2, X-3, X-4. [pmid: 21126755].
1991 Ojha K, Matah A. Surgical management of chronic pelvic pain. Obstetrics, Gynaecology and Reproductive Medicine. 2008;18(9):236-240. X-1, X-2, X-3.
1992 O'Sullivan PB, Beales DJ. Diagnosis and classification of pelvic girdle pain disorders-Part 1: A mechanism based approach within a biopsychosocial framework. Manual Therapy. 2007;12(2):86-97. X-1, X-2, X-3, X-4. [pmid: 17449432].
1993 Parazzini F, et al. Prevalence and anatomical distribution of endometriosis in women with selected gynaecological conditions: Results from a multicentric Italian study. Human Reproduction. 1994;9(6):1158-1162. X-3, X-4. [pmid: 7962393].
1994 Parker MC, et al. Adhesions and colorectal surgery - Call for action. Colorectal Disease. 2007;9(SUPPL. 2):62-72. X-1, X-2, X-3, X-4.
1995 Parsons CL. The role of a leaky epithelium and potassium in the generation of bladder symptoms in interstitial cystitis/overactive bladder, urethral syndrome, prostatitis and gynaecological chronic pelvic pain. BJU International. 2011;107(3):370-375. X-1, X-2, X-3, X-4. [pmid: 21176078].
1996 Pecukonis EV. Childhood sex abuse in women with chronic intractable back pain. Social Work in Health Care. 1996;23(3):1-16. X-2, X-3, X-4. [pmid: 8865512].
1997 Peipert JF, et al. Association of lower genital tract inflammation with objective evidence of endometritis. Infectious Diseases in Obstetrics and Gynecology. 2000;8(2):83-87. X-2, X-3, X-4. [pmid: 10805362].
1998 Perry CP. Laparoscopic uterovaginal ganglion excision (LUVE) for chronic pelvic pain. Journal of Gynecologic Surgery. 1996;12(2):89-93. X-3.
1999 Pfisterer J, et al. The anti-idiotypic antibody abagovomab in patients with recurrent ovarian cancer. A phase I trial of the AGO-OVAR. Annals of Oncology. 2006;17(10):1568-1577. X-2, X-3, X-4. [pmid: 17005631].
2000 Povolny B. Acupuncture and traditional Chinese medicine: an overview. Techniques in Regional Anesthesia and Pain Management. 2008;12(2):109-110. X-1, X-2, X-3, X-4.
2001 Reid BA, et al. Long-term results of bilateral oophorectomy for the treatment of chronic pelvic pain: Relief of pain and special hormone replacement therapy requirements. Journal of Obstetrics and Gynaecology. 1996;16(6):538-543. X-2, X-3.
2002 Reig E, et al. Thermocoagulation of the ganglion impar or ganglion of Walther: Description of a modified approach. Preliminary results in chronic, nononcological pain. Pain Practice. 2005;5(2):103-110. X-2, X-3, X-4. [pmid: 17177756].
2003 Reiter RC, Gambone JC, Johnson SR. Availability of a multidisciplinary pelvic pain clinic and frequency of hysterectomy for pelvic pain. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):109-116. X-3, X-4, X-5.
2004 Riggs RM, McCarthy JM, Kaufman L. The utility of the beck depression inventory in the evaluation of chronic pelvic pain patients. Journal of Gynecologic Surgery. 2007;23(4):127-132. X-3.
2005 Roberts RO, et al. Prevalence of a physician-assigned diagnosis of prostatitis: The olmsted county study of urinary symptoms and health status among men. Urology. 1998;51(4):578-584. X-2, X-3, X-4. [pmid: 9586610].
2006 Roghaei MA, et al. Effects of Letrozole compared with Danazol on patients with confirmed endometriosis: A randomized clinical trial. International Journal of Fertility and Sterility. 2010;4(2):67-72. X-2.
2007 Rosenthal RH, et al. Assessing chronic pelvic pain: Clinical use of the Eysenck Personality Questionnaire. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):31-38. X-4.
2008 Rozati R, et al. The CYP1A1 and GSTM1 genetic polymorphisms and susceptibility to endometriosis in women from South India. International Journal of Fertility and Sterility. 2008;2(3):105-112. X-4.
2009 Sadek K, et al. Hypothesis: Role for the circadian Clock system and sleep in the pathogenesis of adhesions and chronic pelvic pain?. Medical Hypotheses. 2011;76(3):453-456. X-1, X-2, X-3, X-4. [pmid: 21146320].
2010 Samantha MB, Leserman J. Psychiatric comorbidity in women with chronic pelvic pain. CNS Spectrums. 2011;16(2). X-1, X-3.
2011 Santanam N, et al. Fertility and Sterility. Conference: Annual Meeting of the American Society for Reproductive Medicine, ASRM. 2010;94(4 SUPPL. 1). X-2, X-3, X-4.
2012 Savidge CJ, et al. Women's perspectives on their experiences of chronic pelvic pain and medical care. Journal of Health Psychology. 1998;3(1):103-116. X-3, X-4. [pmid: 22021346].
2013 Schneider JP, Kirsh KL. Defining clinical issues around tolerance, hyperalgesia, and addiction: A quantitative and qualitative outcome study of long-term opioid dosing in a chronic pain practice. Journal of Opioid Management. 2010;6(6):385-395. X-2, X-3, X-4. [pmid: 21268999].
2014 Servy EJ, Kaufmann RA, Aksu MF. Extra corporeal abdominal hysterectomy: Via mini laparotomy an alternative to laparoscopic uterine removal. Marmara Medical Journal. 2001;14(4):227-231. X-2, X-3, X-4, X-5.
2015 Shafik A, Ratcliffe N, Wright JT. The importance of histological diagnosis in patients with chronic pelvic pain and laparoscopic evidence of endometriosis. Gynaecological Endoscopy. 2000;9(5):301-304. X-3, X-4.
2016 Sheikh HH. Recurrent adnexal torsion and cystadenoma of aberrant ovarian tissue. Southern Medical Journal. 1991;84(8):1037-1038. X-1, X-2, X-3, X-4. [pmid: 1882257].
2017 Shoskes DA, et al. Journal of Urology. Conference. 2009;181(4 SUPPL. 1). X-2, X-3, X-4.
2018 Siddall-Allum J, et al. Chronic pelvic pain caused by residual ovaries and ovarian remnants. British Journal of Obstetrics and Gynaecology. 1994;101(11):979-985. X-3. [pmid: 7999729].
2019 Slavin RE, Krum R, Dinh TV. Endometriosis-associated intestinal tumors: A clinical and pathological study of 6 cases with a review of the literature. Human Pathology. 2000;31(4):456-463. X-2, X-3, X-4. [pmid: 10821493].
2020 Smith CB. Chronic pelvic pain: Why empathy and listening are the keys to diagnosis. Consultant. 1997;37(1):161-170. X-1, X-2, X-3, X-4.
2021 Smith RP, Metheny WP, Nolan TE. A tool for the assessment of chronic pelvic pain. Journal of Psychosomatic Obstetrics and Gynaecology. 1992;13(4):281-286. X-4.
2022 Stephens SC, et al. Can case reports be used to identify trends in pelvic inflammatory disease? San Francisco, 2004-2009. Sexually Transmitted Diseases. 2011;38(1):8-11. X-2, X-3, X-4. [pmid: 20661177].
2023 Stepniewska A, et al. Laparoscopic treatment of bowel endometriosis in infertile women. Human Reproduction. 2009;24(7):1619-1625. X-2, X-3, X-4. [pmid: 19357136].
2024 Stoller ML, et al. Ureteroscopy without routine balloon dilation: An outcome assessment. Journal of Urology. 1992;147(5):1238-1242. X-2, X-4. [pmid: 1569657].
2025 Stratton P. The tangled web of reasons for the delay in diagnosis of endometriosis in women with chronic pelvic pain: will the suffering end?. Fertility and Sterility. 2006;86(5):1302-1304. X-1, X-3, X-4. [pmid: 17070184].
2026 Sutton C, et al. A prospective, randomized, double-blind controlled trial of laparoscopic uterine nerve ablation in the treatment of pelvic pain associated with endometriosis. Gynaecological Endoscopy. 2001;10(4):217-222. X-3.
2027 Theodorou C, et al. The urodynamic profile of prostatodynia. BJU International. 1999;84(4):461-463. X-2, X-3, X-4. [pmid: 10468762].
2028 Tripoli TM, et al. Evaluation of Quality of Life and Sexual Satisfaction in Women Suffering from Chronic Pelvic Pain With or Without Endometriosis. Journal of Sexual Medicine. 2011;8(2):497-503. X-2, X-3, X-4, X-5. [pmid: 20722779].
2029 Tu FF, et al. Vaginal pressure-pain thresholds: Initial validation and reliability assessment in healthy women. Clinical Journal of Pain. 2008;24(1):45-50. X-2, X-3, X-4. [pmid: 18180636].
2030 van Valkengoed IGM, et al. Overestimation of complication rates in evaluations of Chlamydia trachomatis screening programmes - Implications for cost-effectiveness analyses. International Journal of Epidemiology. 2004;33(2):416-425. X-2, X-3, X-4. [pmid: 15082651].
2031 Van Wingerden JP, Vleeming A, Ronchetti I. Differences in standing and forward bending in women with chronic low back or pelvic girdle pain: Indications for physical compensation strategies. Spine. 2008;33(11):E334-E341. X-4. [pmid: 18469680].
2032 Volpi E, et al. Laparoscopic treatment of endometrial cancer: Feasibility and results. European Journal of Obstetrics Gynecology and Reproductive Biology. 2006;124(2):232-236. X-2, X-3, X-4.
2033 Walker EA, et al. The prevalence of chronic pelvic pain and irritable bowel syndrome in two university clinics. Journal of Psychosomatic Obstetrics and Gynaecology. 1991;12(SUPPL):65-75. X-3.
2034 Warren JW, et al. Sexuality and reproductive risk factors for interstitial cystitis/painful bladder syndrome in women. Urology. 2011;77(3):570-575. X-2, X-3, X-4. [pmid: 21215994].
2035 Warren JW, et al. Numbers and types of nonbladder syndromes as risk factors for interstitial cystitis/painful bladder syndrome. Urology. 2011;77(2):313-319. X-2, X-3, X-4. [pmid: 21295246].
2036 Wesselmann U, et al. Emerging therapies and novel approaches to visceral pain. Drug Discovery Today: Therapeutic Strategies. 2009;6(3):89-95. X-1, X-2, X-3, X-4. [pmid: 21243067].
2037 Wiborny R, Pichler B. Endoscopic dissection of the uterosacral ligaments for the treatment of chronic pelvic pain. Gynaecological Endoscopy. 1998;7(1):33-35. X-3.
2038 Xu HM, et al. Characteristics of pathological findings in women with chronic pelvic pain using conscious mini-laparoscopic pain mapping. Chinese Medical Journal. 2010;123(24):3706-3710. X-4. [pmid: 22166654].
2039 Zerem E, Imamovic G, Omerovic S. Percutaneous Drainage without Sclerotherapy for Benign Ovarian Cysts. Journal of Vascular and Interventional Radiology. 2009;20(7):921-925. X-2, X-3, X-4. [pmid: 19555887].
2040 Zhang GX, et al. A preliminary evaluation of the psychometric profiles in Chinese men with chronic prostatitis/chronic pelvic pain syndrome. Chinese Medical Journal. 2011;124(4):514-518. X-2, X-3, X-4. [pmid: 21362273].
2041 Zondervan KT, et al. The prevalence of chronic pelvic pain in women in the United Kingdom: A systematic review. British Journal of Obstetrics and Gynaecology. 1998;105(1):93-99. X-1. [pmid: 9442169].
2042 Zullo F, et al. Efficacy of laparoscopic pelvic denervation in central-type chronic pelvic pain: A multicenter study. Journal of Gynecologic Surgery. 1996;12(1):35-40. X-1, X-2, X-3.