# Search Strategies

Last updated May 3, 2011

Table A1 PubMed search results

Search terms | | Preliminary search results
#1 | “chronic pelvic pain” | 1932
#2 | chronic OR recurrent OR recurring OR chronic disease[mh] OR noncyclic OR non-cyclic OR mixed | 1141198
#3 | “pelvic pain” OR pelvic pain[mh] | 8305
#4 | (musculoskeletal diseases[mh] OR myofascial[tiab]) AND (pelvic[tiab] OR pelvis[tiab] OR pelvis[mh] OR pelvic pain[tiab]) | 7333
#5 | #1 OR (#2 AND (#3 OR #4)) AND eng[la] AND humans[mh] AND 1990:2011[dp] | 2337
#6 | #5 AND case reports[pt] | 396
#7 | #5 AND letter[pt] | 52
#8 | #5 AND comment[pt] | 61
#9 | #5 AND editorial[pt] | 29
#10 | #5 AND review[pt] | 609
#11 | #5 AND meta-analysis[pt] | 13
#12 | #5 AND practice guideline[pt] | 14
#13 | #5 NOT (#6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12) | 1280

Key: [mh] Medical Subject Heading; [la] language; [pt] publication type; [dp] publication date; [tiab] title/abstract word

* 32 new items in May 2011 update

Table A2 CINAHL search results

Search terms | | Preliminary search results
#1 | ((MH “Chronic Pain”) OR (MH “Chronic Disease”) OR chronic OR recurrent OR recurring OR noncyclic OR non-cyclic OR mixed) AND (pelvic pain OR (MH “Pelvic Pain”)), limited to English language, human, research articles, and citations published since 1990; MEDLINE records excluded | 23
#2 | ((MH “Musculoskeletal Diseases+”) OR myofascial ) AND (pelvic OR pelvis), limited to English language, human, research studies, and citations published since 1990; MEDLINE records excluded | 59
#3 | #1 OR #2 | 79
#4 | #3 AND PT doctoral dissertation | 7
#5 | #3 AND PT systematic review | 5
#6 | #3 NOT (#4 OR #5) | 67

Key: MH medical subject word; PT publication type

* 7 new items in May 2011 update

Table A3 PsycINFO results (CSA interface)

Search terms | | Preliminary search results
#1 | KW=(chronic or recurrent or recurring) or DE=(“chronic illness” or “chronic pain”) | 92687
#2 | KW=(pelvic pain) | 309
#3 | KW=(pelvic or pelvis) and (DE=(“musculoskeletal disorders” or “myofascial pain”) or KW=(myofascial)) | 7
#4 | #1 AND (#2 OR #3), limited to English language, human, peer-reviewed journals, and items published between 1990 and 2011 | 149
#5 | #4 and PT=(letter) | 2
#6 | #4 and PT=(comment/reply) | 7
#7 | #4 and PT=(editorial) | 1
#8 | #4 and PT=(book) | 1
#9 | #4 and PT=(abstract collection) | 1
#10 | #4 not (#5 OR #6 OR #7 OR #8 OR #9) | 136

Key: PT publication type; DE descriptor/subject term

Note: No new items retrieved in May 2011 update

Table A4 EMBASE results (1988–2011 file)

Search terms | | Preliminary search results
#1 | (chronic or recurrent or recurring or noncyclic or non-cyclic or mixed or chronic disease/ or chronic illness/ or chronic pain/) | 1087381
#2 | pelvic pain.mp. or pelvic pain syndrome/ | 8390
#3 | (musculoskeletal disease/ or musculoskeletal pain/ or myofascial pain/) and (pelvis/ or pelvic.mp.) | 241
#4 | #1 AND (#2 OR #3), limited to English language; human; items published between 1990 and 2011; database source=EMBASE | 2312
#5 | #4 and conference paper.pt. | 120
#6 | #4 and review.pt | 571
#7 | #4 and short survey.pt | 31
#8 | #4 and book.pt | 5
#9 | #4 and editorial.pt | 34
#10 | #4 and letter.pt | 57
#11 | #4 and note.pt | 49
#12 | #4 and case report/ | 287
#13 | #4 and practice guideline/ | 54
#14 | #4 and “systematic review”/ | 31
#15 | #4 and meta analysis/ | 15
#16 | #4 not (#5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 OR #13 OR #14 OR #15) | 1161

Key: .pt publication type; .mp keyword

Note: With May 2011 update, changed from EMBASE Drugs and Pharmacology to full EMBASE database; 738 new items retrieved in May 2011. After eliminating 498 citations duplicated by the other database retrieval sets, 240 unique items were included in the update.