# Appendixes

Appendix A Search Strategies

Appendix B Excluded Studies

Appendix C Evidence Tables

Appendix D Data Extraction Forms

Appendix E Quality of the Literature

Appendix F Applicability Tables

Appendix G Ongoing and Recently Completed Intervention Studies