# Acknowledgments

We are indebted to a tireless group of colleagues who made this report possible. Each step of systematic reviews draws on the skills and attention of an entire team.

We are grateful for the guidance and methodologic and editing expertise of Dr. Melissa McPheeters, who provided invaluable input for structuring the review and our approach to the literature.

Dr. Mark Hartmann brought his attention to detail—and his commitment to perfection—to completion of the evidence tables. His ability to point out inconsistencies and enhance uniformity was key to ensuring smooth development of the evidence tables.

Dr. Shanthi Krishnaswami provided an exacting and thorough approach to abstract and full-text review and developing evidence tables. Her input was key in ensuring that all relevant data were extracted and that tables were consistent.

Ms. Kathy Lee provided valuable research assistance on this report, helping with logistics, checking and formatting tables, and locating citations.

Ms. Rachel Bazan and Mr. Michael Tranchina were our energetic student workers. They spent hours helping to track and file documents and were always positive and always ready to ensure that the project investigators had what they needed to complete this review.