# Technical Expert Panel

Carl W. Bazil, M.D., Ph.D.

Caitlin Tynan Doyle Professor of Clinical Neurology

Director, Division of Comprehensive Epilepsy Center and Sleep Center

Columbia University College of Physicians and Surgeons

New York, NY

Brien Smith, M.D.

Medical Director

Comprehensive Epilepsy Program

Henry Ford Hospital

Detroit, MI

Dena R. Hixon, Ph.D.

Food and Drug Administration

Office of Generic Drugs

Washington, DC

Michel J. Berg, M.D.

Associate Professor

University of Rochester Medical Center

Director, Strong Epilepsy Center

Rochester, NY

Gail D. Anderson Ph.D.

Professor, Departments of Pharmacy, Pharmaceutics (adj) and Neurological Surgery (adj).

University of Washington

Health Science Complex

Seattle, WA