# Summary and Discussion

Our general results with strength of evidence rating are given in Table 10. Only one outcome, the risk of gum hyperplasia with phenytoin versus newer antiepileptic medications, had a high strength of evidence. For the outcomes reported in the discussion above, the strength of evidence was predominantly moderate to low for the newer versus older antiepileptic medication evaluation and low to insufficient for the innovator versus generic evaluation. In many cases, strength of evidence was reduced for issues of inconsistency and imprecision. Pooling multiple newer antiepileptic medication comparisons versus a single older antiepileptic medication enhanced power to detect differences but reduced consistency. Precision was frequently impacted negatively by having only a few small trials for an analysis. Analyses with only observational studies had a greater risk of bias which negatively impacted strength of evidence.

Table 10 Summary of results and strength of evidence

Outcome | Type and Number of Studies | Pooled | Result/Conclusion | Strength of Evidence
KEY QUESTION 1 ENDPOINTS
MORTALITY:
Newer vs. Carbamazepine | 6 RCTs | Yes | No effect, RR 0.75 (0.51, 1.12) | SOE: L
Newer vs. Phenytoin | 3 RCTs | Yes | No effect, RR 0.30 (0.05, 1.95) | SOE: L
Newer vs. Valproic Acid | 3 RCTs | Yes | No effect, RR 0.94 (0.31, 2.80) | SOE: L
OUTPATIENT SERVICE UTILIZATION:
Innovator vs. Generic | 4 OBS | No | Similar utilization of outpatient services during generic medication periods. | SOE: L
HOSPITALIZATIONS:
Newer vs. Carbamazepine | 1 RCT | No | Newer antiepileptic medications (lamotrigine) did not reduce the risk of hospitalization compared with carbamazepine. | SOE: I
Newer vs. Valproic Acid | 1 RCT | No | Newer antiepileptic medications (lamotrigine) did not reduce the risk of hospitalization compared with valproic acid. | SOE: I
Newer vs. Ethosuximide | 1 RCT | No | Newer antiepileptic medications (lamotrigine) did not reduce the risk of hospitalization compared with ethosuximide. | SOE: I
Innovator vs. Generic | 4 OBS | No | Increased risk of hospitalizations during generic medication periods. | SOE: L
HOSPITAL STAY DURATION:
Innovator vs. Generic | 4 OBS | No | Increased hospital stay during generic medication periods. | SOE: L
COMPOSITE OF MEDICAL SERVICE UTILIZATION (Ambulance service, hospitalization, or emergency department visit for epilepsy):
Innovator vs. Generic | 3 OBS | No | Increase in medical service utilization during periods when a patient's antiepileptic medication is switched to an “A” rated version of the product (innovator to generic, generic to generic, generic to innovator). | SOE: I
HEALTH-RELATED QUALITY OF LIFE:
Newer vs. Carbamazepine | 3 RCTs | No | Different scales and subscales, data inconclusive | SOE: I
Newer vs. Carmabazepine CR/SR | 1 RCT | No | Different scales and subscales, data inconclusive | SOE: I
Newer vs. Phenytoin | 2 RCTs | No | Different scales and subscales, data inconclusive | SOE: I
Newer vs. Valproic Acid | 3 RCTs | No | Different scales and subscales, data inconclusive | SOE: I
TIME TO FIRST SEIZURE:
Newer vs. Carbamazepine | 4 RCTs | Yes | No effect, (HR 1.14 [0.98, 1.33]) | SOE: L
Newer vs. Phenytoin | 2 RCTs | Yes | Time to seizure increased for newer vs. phenytoin. (HR 1.59 [1.04, 2.43]) | SOE: L
Newer vs. Valproic Acid | 1 RCT | Yes | No effect, (HR 0.8 [0.63, 1.02]) | SOE: L
SEIZURE OCCURRENCE:
Innovator vs. Generic | 7 RCTs | Yes | No effect, (0.87 [0.64, 1.18]) | SOE: L
SEIZURE FREEDOM FOR STUDY DURATION:
Newer vs. Carbamazepine | 15 RCTs | Yes | No effect, (RR 0.94 [0.87, 1.03]) | SOE: L
Newer vs. Carbamazepine CR/SR | 2 RCTs | Yes | No effect, (RR, 0.90 [0.79, 1.02]) | SOE: M
Newer vs. Phenytoin | 4 RCTs | Yes | No effect, (RR 0.92 [0.85, 1.00]) | SOE: M
Newer vs. Valproic Acid | 12 RCTs | Yes | No effect, (RR 0.97 [0.87, 1.08]) | SOE: M
SEIZURE FREQUENCY:
Newer vs. Carbamazepine | 1 RCT | No | No effect, (MD -3 [-6.32, 0.32]) | SOE: I
Newer vs. Phenytoin | 2 RCTs | No | Not enough data to evaluate effect | SOE: I
Newer vs. Valproic Acid | 1 RCT | No | Not enough data to evaluate effect | SOE: I
Innovator vs. Generic | 3 RCTs | Yes | No effect, (SMD 0.03 [-0.08, 0.14]) | SOE: L
SEIZURE REMISSION 6- to 12-Month:
Newer vs. Carbamazepine | 2 RCTs | Yes | Patients on newer antiepileptic medications were less likely to have seizure remission vs. carbamazepine. (RR 0.81 [0.67, 0.99], NNT 9) | SOE:L
Newer vs. Valproic Acid | 1 RCT | Yes | No effect, (RR 0.97 [0.89,1.06]) | SOE: M
24-Month:
Newer vs. Carbamazepine | 1 RCT | Yes | Patients on newer antiepileptic medication were less likely to have seizure remission vs. carbamazepine. (RR 0.82 [0.72, 0.94], NNT 13) | SOE: M
Newer vs. Valproic Acid | 1 RCT | Yes | No effect, (RR 0.85 [0.73,1.00]) | SOE: M
STATUS EPILEPTICUS, SECONDARY INJURY FROM SEIZURES, LOSS OF DRIVER'S LICENSE/EMPLOYMENT:
Innovator vs. Generic | No data | No | No data | SOE: I
TOTAL WITHDRAWALS:
Newer vs. Carbamazepine | 14 RCTs | Yes | No effect, (RR 0.90 [0.82, 1.00]) | SOE: L
Newer vs. Carbamazepine CR/SR | 2 RCTs | Yes | No effect, (RR 0.96 [0.78, 1.18]) | SOE: L
Newer vs. Phenytoin | 3 RCTs | Yes | No effect, (RR 0.91 [0.76, 1.09]) | SOE: L
Newer vs. Valproic Acid | 16 RCTs | Yes | No effect, (RR 0.96 [0.85, 1.09]) | SOE: L
Newer vs. Ethosuximide | 1 RCT | No | No effect, (RR 0.95 [0.53, 1.71]) | SOE: I
Innovator vs. Generic | 9 RCTs + 1 NRCT | Yes | No effect, (RR 0.90 [0.39, 2.08]) | SOE: L
WITHDRAWALS DUE TO LACK OF EFFICACY:
Newer vs. Carbamazepine | 10 RCTs | Yes | Withdrawals due to lack of efficacy increased with newer agents vs. carbamazepine. (RR 1.59 [1.25, 2.02], NNT 50) | SOE: L
Newer vs. Carbamazepine CR/SR | 1 RCT | No | Withdrawals due to lack of efficacy increased with newer agents vs. carbamazepine CR/SR. (RR 2.43 [1.32, 4.52], NNT 16) | SOE: I
Newer vs. Phenytoin | 3 RCTs | Yes | No effect, (RR 1.03 [0.33, 3.23]) | SOE: L
Newer vs. Valproic Acid | 11 RCTs | Yes | No effect, (RR 1.10 [0.77, 1.56]) | SOE: L
Innovator vs. Generic | 9 RCTs + 1 NRCT | Yes | No effect, (RR 1.02 [0.41, 2.54]) | SOE: L
KEY QUESTION 2 ENDPOINTS
Maximum Concentration:
Innovator vs. Generic | 7 RCTs + 1 NRCT | Yes | No effect, (SMD 0.10 [-0.13, 0.32]) | SOE: L
Minimum Concentration:
Innovator vs. Generic | 5 RCTs + 1 NRCT | Yes | No effect, (SMD 0.05 [-0.21, 0.31]) | SOE: L
Steady State Concentration:
Innovator vs. Generic | 7 RCTs | Yes | No effect, (SMD 0.18 [-0.09, 0.45]) | SOE: L
Time to Maximal Concentration:
Innovator vs. Generic | 5 RCTs | Yes | No effect, (WMD 0.00 [-0.43, 0.43]) (Note: a WMD was calculated vs. an SMD for Tmax because only carbamazepine trials made up this evaluation). | SOE: I
AREA UNDER THE CURVE:
Innovator vs. Generic | 7 RCTs + 1 NRCT | Yes | No effect, (SMD 0.05 [-0.18, 0.28]) | SOE: L
DOSE REQUIREMENTS FOR SEIZURE CONTROL:
Innovator vs. Generic | No data | No | No data | SOE: I
SWITCHBACK RATES:
Innovator vs. Generic | 4 OBS | No | Switchback rates from a generic back to an innovator antiepileptic medication varied from 12.4% to 44.1% | SOE: L
KEY QUESTION 3 ENDPOINTS
WITHDRAWALS DUE TO ADVERSE EVENTS:
Newer vs. Carbamazepine | 18 RCTs | Yes | Withdrawals due to adverse events were reduced with newer antiepileptic medications vs. carbamazepine. (RR 0.62 [0.53, 0.73], NNT 13) | SOE: M
Newer vs. Carbamazepine CR/SR | 2 RCTs | Yes | Withdrawals due to adverse events were reduced with newer antiepileptic medications vs. carbamazepine CR/SR. (RR 0.69 [0.50, 0.95], NNT 16) | SOE: M
Newer vs. Phenytoin | 3 RCTs | Yes | No effect, (0.38 [0.14, 1.03]) | SOE: I
Newer vs. Valproic Acid | 16 RCTs | Yes | No effect, (RR 0.90 [0.75, 1.08]) | SOE: L
Newer vs. Ethosuximide | 1 RCT | No | No effect, (RR 0.71 [0.45, 1.12]) | SOE: I
Innovator vs. Generic | 9 RCTs + 1 NRCT | Yes | No effect, (RR 0.79 [0.28, 2.20]) | SOE: L
HEADACHE:
Newer vs. Carbamazepine | 15 RCTs | Yes | No effect, (RR 0.92 [0.78, 1.08]) | SOE: L
Newer vs. Carbamazepine SR/CR | 2 RCTs | Yes | No effect, (RR 0.83 [0.63, 1.10]) | SOE: L
Newer vs. Phenytoin | 4 RCTs | Yes | No effect, (RR 0.74[0.53, 1.02]) | SOE: L
Newer vs. Valproic Acid | 15 RCTs | Yes | No effect, (RR 0.90 [0.70, 1.16]) | SOE: L
Newer vs. Ethosuximide | 1 RCT | No | No effect, (RR 0.66 [0.33, 1.29]) | SOE: I
Innovator vs. Generic | 3 RCTs | Yes | No effect, (RR 0.95 [0.55, 1.64]) | SOE: I
FATIGUE:
Newer vs. Carbamazepine | 7 RCTs | Yes | Risk of fatigue reduced with newer antiepileptic medications vs. carbamazepine. (RR 0.57 [0.41, 0.80], NNT 11) | SOE: L
Newer vs. Carbamazepine SR/CR | 1 RCT | Yes | No effect, (RR 1.17 [0.80, 1.72]) | SOE: I
Newer vs. Phenytoin | 1 RCT | No | No effect, (RR 1.05 [0.49, 2.25]) | SOE: I
Newer vs. Valproic Acid | 8 RCTs | Yes | Risk of fatigue reduced with newer antiepileptic medications vs. valproic acid. (RR 0.61 [0.44, 0.85], NNT 23) | SOE: M
Newer vs. Ethosuximide | 1 RCT | No | No effect, (RR 0.90 [0.45, 1.80]) | SOE: I
Innovator vs. Generic | No data | No | No data | SOE: I
SOMNOLENCE:
Newer vs. Carbamazepine | 8 RCTs | Yes | Risk of somnolence reduced with newer antiepileptic medications vs. carbamazepine. (RR 0.47 [0.36, 0.61], NNT 14) | SOE: M
Newer vs. Carbamazepine SR/CR | 1 RCT | No | No effect, (RR 1.21 [0.75, 1.96]) | SOE: I
Newer vs. Phenytoin | 4 RCTs | Yes | No effect, (RR 0.72 [0.44, 1.18]) | SOE: I
Newer vs. Valproic Acid | 9 RCTs | Yes | Risk of somnolence reduced with newer antiepileptic medications vs. valproic acid. (RR 0.65 [0.43, 0.98], NNT 25) | SOE: M
Newer vs. Ethosuximide | 1 RCT | No | Risk of somnolence reduced with newer antiepileptic medications vs. ethosuximide. (RR 0.22 [0.07, 0.70], NNT 15) | SOE: I
Innovator vs. Generic | 2 RCTs | Yes | No effect, (RR 0.90 [0.48, 1.70]) | SOE: L
DIZZINESS:
Newer vs. Carbamazepine | 16 RCTs | Yes | Risk of dizziness reduced with newer antiepileptic medications vs. carbamazepine. (RR 0.78 [0.67, 0.91], NNT 50) | SOE: M
Newer vs. Carbamazepine SR/CR | 2 RCTs | Yes | No effect, (RR 0.96 [0.56, 1.66]) | SOE: L
Newer vs. Phenytoin | 3 RCTs | Yes | No effect, (RR 0.67 [0.43, 1.05]) | SOE: L
Newer vs. Valproic Acid | 12 RCTs | Yes | No effect, (RR 0.98 [0.71, 1.35]) | SOE: L
Newer vs. Ethosuximide | 1 RCT | No | No effect, (RR 0.46 [0.15, 1.38]) | SOE: I
Innovator vs. Generic | No data | No | No data | SOE: I
COMBINED NEUROLOGICAL ADVERSE EVENTS:
Innovator vs. Generic | 1 RCT + 1 OBS | No | No effect, RCT: 4.3% vs 21.7%, p=0.189; OBS: 75.7 events per 1,000 person years, 75.7 events per 1,000 person years, p=NS | SOE: L
DIPLOPIA:
Innovator vs. Generic | 2 RCT | Yes | No effect, (1.28 [0.38, 4.31]) | SOE: L
HYPOTENSION, ASTHENIA, ATAXIA, NYSTAGMUS, TREMOR:
Innovator vs. Generic | No data | No | No data | SOE: I
NAUSEA:
Newer vs. Carbamazepine | 8 RCTs | Yes | No effect, (RR 0.69 [0.46, 1.02]) | SOE: L
Newer vs. Carbamazepine SR/CR | 1 RCT | No | No effect, (RR 0.66 [0.39, 1.12]) | SOE: I
Newer vs. Phenytoin | 4 RCTs | Yes | No effect, (RR 0.88 [0.56, 1.37]) | SOE: L
Newer vs. Valproic Acid | 11 RCTs | Yes | Risk of nausea reduced with newer antiepileptic medications vs. valproic acid. (RR 0.56 [0.41, 0.77], NNT 31) | SOE: M
Innovator vs. Generic | No data | No | No data | SOE: I
VOMITING:
Newer vs. Carbamazepine | 3 RCTs | Yes | No effect, (RR 1.25 [0.66, 2.35]) | SOE: L
Newer vs. Phenytoin | 1 RCT | No | Risk of vomiting was reduced with newer antiepileptic medications vs. phenytoin. (RR 0.09 [0.01, 0.89], NNT 19) | SOE: I
Newer vs. Valproic Acid | 5 RCTs | Yes | No effect, (RR 0.69 [0.34, 1.42]) | SOE: L
Innovator vs. Generic | No data | No | No data | SOE: I
SKIN RASH:
Newer vs. Carbamazepine | 13 RCTs | Yes | Risk of skin rash was reduced with newer antiepileptic medications vs. carbamazepine. (RR 0.52 [0.39, 0.69], NNT 24) | SOE: M
Newer vs. Carbamazepine SR/CR | 2 RCTs | Yes | Risk of skin rash was reduced with newer antiepileptic medications vs. carbamazepine SR/CR. (RR 0.47 [0.25, 0.89], NNT 27) | SOE: L
Newer vs. Phenytoin | 4 RCTs | Yes | No effect, (RR 0.76 [0.34, 1.66]) | SOE: I
Newer vs. Valproic Acid | 10 RCTs | Yes | No effect, (RR 1.17 [0.55, 2.48]) | SOE: L
Innovator vs. Generic | 2 RCTs | Yes | No effect, (RR 0.77 [0.17, 3.57]) | SOE: I
SUICIDAL IDEATION:
Newer vs. Carbamazepine | 1 Obs | No | Risk of attempted suicide was increased with gabapentin vs. carbamazepine. (RR 13.92 [1.82, 106.38]) | SOE: I
Innovator vs. Generic | No data | No | No data | SOE: I
MOOD AND COGNITION:
Newer vs. Carbamazepine | 4 RCTs | No | Different scales and subscales, data inconclusive | SOE: I
Newer vs. Phenytoin | 1 RCT | No | No effect | SOE: I
Newer vs. Valproic Acid | 5 RCTs | No | Different scales and subscales, data inconclusive | SOE: I
Innovator vs. Generic | 1 RCT | No | Only cognition evaluated. No significant differences between innovator of generic but 4 of 5 cognitive test measures showed better scores for innovator than generic. | SOE: I
BONE DENSITY:
Newer vs. Older | No data | No | No data | SOE: I
Innovator vs. Generic | No data | No | No data | SOE: I
ALOPECIA:
Newer vs. Carbamazepine | 6 RCTs | Yes | No effect, (RR 0.60 [0.23, 1.58]) | SOE: L
Newer vs. Valproic Acid | 8 RCTs | Yes | Risk of alopecia was reduced with newer antiepileptic medications vs. valproic acid. (RR 0.18 [0.10, 0.31), NNT 10] | SOE: M
ACNE:
Newer vs. Phenytoin | 1 RCT | No | No effect, (RR 2.78 [0.82, 9.53]) | SOE: I
GUM HYPERPLASIA:
Newer vs. Phenytoin | 2 RCTs | Yes | Risk of gum hyperplasia was reduced with newer antiepileptic medications vs. phenytoin. (RR 0.10 [0.04, 0.27], NNT 6) | SOE: H

Legend: CR = controlled release; H = high; I = insufficient; L = low; M = moderate; MD = mean difference; SMD = standardized mean difference; NRCT = nonrandomized controlled trial; NNT = number needed to treat; OBS = observational study; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence; SR = sustained release; WMD = weighted mean difference

Applicability of evidence for both the newer versus older antiepileptic medication evaluation and the innovator versus generic evaluation was more evenly dispersed between insufficient, low, and moderate with no areas of high applicability. For the innovator versus generic evaluations, the lack of specification that the products were “A” rated generics and the multitude of studies conducted outside the United States limited applicability.

## Older Versus Newer Evaluation

No significant difference in the risk of maintaining seizure freedom was seen when newer antiepileptic medications were compared versus carbamazepine, controlled/sustained release carbamazepine, phenytoin, or valproic acid in controlled clinical trials. The risk of being seizure free for either 12 or 24 months was significantly lower for newer antiepileptic agents versus carbamazepine. No differences in 12- or 24-month seizure freedom were seen for newer antiepileptic medications versus valproic acid although this was based on a single controlled clinical trial. There was a significant increase in the time to first seizure when newer antiepileptic medications were compared versus phenytoin. No difference in the time to first seizure was seen between newer antiepileptic medications versus carbamazepine or valproic acid.

Withdrawals can be due to lack of efficacy, adverse events, or other factors. We could not find any significant difference in the risk of withdrawing for any reason when newer antiepileptic medications were compared with carbamazepine, controlled/sustained release carbamazepine, ethosuximide, phenytoin, or valproic acid. However, in the case of carbamazepine and controlled/sustained release carbamazepine, this was due to an offsetting significant increase in the risk of withdrawals due to lack of efficacy and a significant decrease in withdrawals due to adverse events.

In this analysis we compared newer antiepileptic medications to older epileptic medications for dizziness, fatigue, headache, nausea, skin rash, and somnolence. Taken together, patients taking newer antiepileptic medications had a significantly lower risk of developing dizziness, fatigue, skin rash, and somnolence versus those taking carbamazepine. Patients taking newer antiepileptic medications had a significantly lower risk of developing fatigue, nausea, and somnolence versus those patients taking valproic acid. In many cases, the controlled/sustained release carbamazepine and phenytoin analyses were based on limited data. However, the risk of skin rash was significantly lower with newer antiepileptic medications versus controlled/sustained release carbamazepine. The risk of vomiting was significantly reduced when newer antiepileptic medications were compared versus phenytoin. For cosmetic adverse events, newer antiepileptic medications had a lower risk of alopecia than valproic acid but not versus carbamazepine. Newer antiepileptic medications also had a lower risk of causing gum hyperplasia versus phenytoin.

In total, carbamazepine or controlled/sustained-release carbamazepine have some efficacy advantages over newer antiepileptic medications but have more adverse events and adverse events causing withdrawal. The other older antiepileptic medications agents have similar efficacy versus newer antiepileptic medications and have more adverse events although the adverse events do not lead to a higher rate of withdrawal.

## Innovator Versus Generic Evaluation

For the comparison of innovator antiepileptic medications to their respective generic versions, we found that seizure occurrence and frequency was similar between groups in controlled clinical trials. In addition, there were no differences between innovator antiepileptic medications and their respective generic versions in terms of total withdrawals or withdrawals due to lack of efficacy in controlled clinical trials. In one controlled observational trial, there was a significant increase in withdrawals for any reason, but this study had marked differences in several demographic variables (age, insurance type, and concomitant migraine headache and cerebral palsy), but the study investigators did not conduct adjusted analyses. When viewed together, the data suggests that generic antiepileptic medication use, predominantly with carbamazepine, phenytoin, and valproic acid provides a similar level of efficacy to a population of people with epilepsy as their respective innovator products. While the source of the innovator and the generic (internationally versus domestically) may impact the variability in blood concentrations, the pharmacokinetic and final health outcomes results for initiating innovator versus generic medications seem congruent.

Data on withdrawal rates due to adverse events were only available for innovator versus generic carbamazepine and phenytoin limiting the ability to extrapolate findings to other antiepileptic medications. The withdrawals due to adverse events were similar between the innovator and generic versions of antiepileptic medications. These results are in agreement with the overall withdrawal rates reported in Key Question 1. While our data suggests that tolerability is similar in a population of patients receiving an innovator versus generic version of antiepileptic medication, we cannot say that an individual patient would not have changes in tolerability upon switching either due to changes in pharmacokinetics or as a result of the anxiety that they feel from switching. Data on combined neurological adverse events was only available for carbamazepine limiting the ability to extrapolate findings to other antiepileptic medications. There was no statistically significant difference in the combined neurological adverse events between the innovator and generic carbamazepine. However, in the single controlled trial and single observational study, the occurrence of neurological adverse events was qualitatively greater. For individual neurological adverse events, data on headache was only reported for carbamazepine and phenytoin, which showed no statistically significant difference between the innovator and generic versions. Data on dizziness, somnolence, and diplopia was only reported for carbamazepine, which also showed no statistically significant difference between the innovator and generic versions carbamazepine. Data on incidence of rash or the impact on cognition was only available for carbamazepine and in both cases showed no statistically significant difference between innovator and generic versions.

Many of the controlled clinical trials used a crossover design or randomized patients to either an innovator or generic product in a parallel fashion so they cannot be used to determine whether a switch from one antiepileptic medication to another “A” rated form of the medication, whether an innovator or generic, would increase the loss of seizure control or adverse events versus maintaining therapy with the same version. Unfortunately this has not been directly assessed in any controlled clinical trial or controlled observational trial.

Four controlled observational trials evaluated the impact of switching from one version of an antiepileptic medication (either an innovator or generic) to another version of the medication on outpatient resource utilization, hospitalization, and hospital stay duration. Two controlled observational trials (one evaluating several antiepileptic medications together as one group and another focusing on lamotrigine) found an increased incidence of utilizing outpatient resources33,129 but two other trials did not.133,162 Of the six analyses evaluating hospitalization rate within these four trials, four analyses found significant increases in hospitalization rates and two found trends toward increases. All four controlled observational studies found a significant increase in hospital length of stay. These observational studies have important limitations. They were evaluating patients who were likely stabilized on the innovator therapy, were switched to the generic medication and were switched back. They cannot be used to assess where the initial use of an innovator or generic antiepileptic medication makes a difference. It is not specified that the generic medications were all “A” rated and if not, the differences noted might not be translatable to “A” rated versions. Since the switch was not blinded, patients and clinicians may have been aware the switch had occurred and emotional or anxiety related triggers for medical service utilization not related to the comparability of the innovator and generic products could have occurred.

Three well conducted controlled observational studies assessed a composite endpoint of medical service utilization. Two of the studies used similar methods, had a similar composite endpoint (emergency department visit, ambulance service utilization, or hospitalization) and derived similar results. They matched for several important factors and limited the analyses to “A” rated products but could not control for comorbidities or changes in other medications. In a third important case control study, no significant difference was found after adjusting for confounders. Unlike the other two trials,126,127 this study authors controlled for person's risk of epilepsy exacerbation, change in disease severity, drug interactions, poor adherence, and change in patient diagnosis.128 This suggests that the difference in magnitude between these three studies may be due to inadequate confounder adjustment. Alternatively, since the first two controlled observational studies used a composite endpoint that included ambulance service utilization while the third study did not, this may also explain differences in magnitude between the three studies.

As such, the data suggests that for initial drug selection, choosing an innovator or generic version of an antiepileptic medication would result in similar efficacy and safety. Preliminary and limited data suggests that switching may have resulted in additional adverse events although the differences could be attributable to confounders which were not well accounted for.