# References

1 Lowenstein DH. Seizures and epilepsy. Fauci AS, Kasper DL, Longo DL, editors. Harrison's principles of internal medicine. 17th ed. New York. McGraw-Hill. 2008. Chapter 369.
2 Scheuer ML, Pedley TA. The evaluation and treatment of seizures. N Engl J Med. 1990;323:1468-74. [pmid: 2233919].
3 Cascino GD, Sharbrough FW. Symposium on epilepsy. Foreword. Mayo Clinic Proc. 1996;71:403-4. [pmid: 8637267].
4 Tatum WO IV, Benbadis S, Vale FL. The neurosurgical treatment of epilepsy. Arch Fam Med. 2000;9:1142-6. [pmid: 11115221].
5 Middleton DB. Seizure disorders. Taylor RB, editor. Family medicine: principles and practice. 6th ed. New York, NY. Springer-Verlag. 2003. Chapter 64.
6 French JA, Kanner AM, Baustista J, et al. Efficacy and tolerability of the new antiepileptic drugs I: treatment of new onset epilepsy: report of therapeutics and technology assessment subcommittee and quality standards subcommittee of the American Academy of Neurology and the American Epilepsy Society. Neurology. 2004;62:1252-60. [pmid: 15111659].
7 Basow DS, editor. UpToDate Online 17.0. Waltham, MA. http://utdol.com/online/content/search.do. April 25, 2009.
8 MD Consult. Drugs. Drug Monograph. www.mdconsult.com/das/pharm/lookup/134025550-4?type=alldrugs. April 25, 2009.
9 Micromedex Healthcare Series [Intranet database]. Version 5.1. Greenwood Village, CO. Thomson Reuters (Healthcare) Inc.
10 Amidon GL, Lenneernas H, Shah VP, et al. A theoretical basis for a biopharmaceutic drug classification: the correlation of in vitro drug product dissolution and in vivo bioavailability. Pharm Res. 1995;12:413-20. [pmid: 7617530].
11 Wu CY, Benet LZ. Predicting drug disposition via application of BCS: transport/absorption/ elimination interplay and development of a biopharmaceutics drug disposition classification system. Pharm Res. 2005;22:11-23. [pmid: 15771225].
12 Lindenberg M, Kopp S, Dressman JB. Classification of orally administered drugs on the World Health Organization Model list of Essential Medicines according to the biopharmaceutics classification system. Eur J Pharm Biopharm. 2004;58:265-78. [pmid: 15296954].
13 Food and Drug Administration. The Biopharmaceutics Classification System (BCS) Guidance. www.fda.gov/AboutFDA/CentersOffices/CDER/ucm128219.htm.
14 Budavari S. The Merck Index. 13th ed. Whitehouse Station, N.J. Merck & Co. 1996.
15 Anderson GD, Miller JW. Benzodiazepines: Chemistry, biotransformation and pharmacokinetics. Levy RH, Mattson RH, Meldrum BS, Perrucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:187-205.
16 Pisani F, Perucca E, Bialer M. Ethosuximide: Chemistry, biotransformation, pharmacokinetics and drug interactions. Levy RH, Meldrun BS, Perrucca E, editors. Antiepileptic drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:646-51.
17 Fincham RW. Primidone. Levy RH, Mattson RH, Meldrum BS, Perrucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:621-35.
18 Kucharczyk N. Felbamate Chemistry and Biotransformation. Levy RH, Mattson RH, Meldrum BS, Perrucca E, editors. Antiepileptic Drugs. 4th ed. New York. Raven Press. 1995:799-806.
19 Pellock JM, Perhach JM, Sofia RD. Felbamate. Levy RH, Mattson RH, Meldrum BS, Perrucca E, editors. Antiepileptic Drugs. Philadelphia. Lippincott Williams & Wilkins. 2002:301-18.
20 Vajda FJE. Chemistry, biotransformation, pharmacokinetics, and interactions. Levy RH, Mattson RH, Meldrum BS, Perrucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:335-43.
21 Dickins M, Sawyer DA, Moreley TJ, et al. Lamotrigine: chemistry and biotransformation. Levy RH, Mattson RH, Meldrum BS, editors. Antiepileptic Drugs. 5th ed. New York. Raven Press. 1995:871-5.
22 Patsalos PM. Levetiracetam: Chemistry, biotransformation, pharmacokinetics and drug interactions. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:428-32.
23 Bialer M. Oxcarbazepine Chemistry, biotransformation and pharmacokinetics. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:459-65.
24 Ben-Menachem E. Pregablin. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. Philadelphia. Lippincott Williams & Wilkins. 2002:901-5.
25 Sommerville KW, Collins SD. Tiagabine Chemistry, biotransformation, and pharmacokinetics. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. Philadelphia. Lippincott Williams & Wilkins. 2002.
26 Doose DR, Streeter AJ. Topiramate: Chemistry, biotransformation and pharmacokinetics. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. Philadelphia. Lippincott Williams & Wilkins. 2002:727-34.
27 Shah J, Shellenberger K, Canafax DM. Zonisamide Chemistry, biotransformation, and pharmacokinetics. Levy RH, Mattson RH, Meldrum BS, Perucca E, editors. Antiepileptic Drugs. 5th ed. Philadelphia. Lippincott Williams & Wilkins. 2002:873-9.
28 Marson AG, Al-Kharusi AM, Alwaidh M, et al. The SANAD study of effectiveness of carbamazepine, gabapentin, lamotrigine, oxcarbazepine, or topiramate for treatment of partial epilepsy: an unblinded randomised controlled trial. Lancet. 2007;369:1000-15. [pmid: 17382827].
29 Marson AG, Al-Kharusi AM, Alwaidh M, et al. The SANAD study of effectiveness of valproate, lamotrigine, or topiramate for generalised and unclassifiable epilepsy: an unblinded randomised controlled trial. Lancet. 2007;369:1016-26. [pmid: 17382828].
30 Assessment: generic substitutionfor antiepileptic medication Report of the therapeutics and technology assessment subcommittee of the American Academy of Neurology. Neurology. 1990;40:1641-3. [pmid: 2234417].
31 Liow K, Barkley GL, Pollard JR, et al. Position statement on the coverage of anticonvulsant drugs for the treatment of epilepsy. Neurology. 2007;68:1249-50. [pmid: 17438213].
32 Percucca E, Albani F, Capovilla G, et al. Recommendations of the Italian League against epilepsy working group on generic products of of antiepileptic drugs. Epilepsia. 2006;47(Suppl 5):16-20. [pmid: 17239100].
33 LeLorier J, Duh MS, Paradis PE, et al. Clinical consequences of generic substitution of lamotrigine for patients with epilepsy. Neurology. 2008;70:2179-86. [pmid: 18505997].
34 American Society of Health-System Pharmacists. Comments from the FDA on narrow therapeutic index drugs and generic substitution. www.ashp.org/import/news/NewsCapsules/article.aspx?id=2. October 22, 2010.
35 Williams RL. Therapeutic equivalence of generic drugs response to National Association of Board of Pharmacy. www.fda.gov/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApprov ed/ApprovalApplications/AbbreviatedNewD rugApplicationANDAGenerics/ucm073224. htm. October 22, 2010.
36 Nightingale SL. Therapeutic equivalence of generic drugs letter to health practitioners. www.fda.gov/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApprov ed/ApprovalApplications/AbbreviatedNewD rugApplicationANDAGenerics/ucm073182. htm. October 22, 2010.
37 National Conference of State Legislatures. 2006 prescription drug state legislation. www.ncsl.org/programs/health/drugbill06.htm. March 19, 2009.
38 National Conference of State Legislatures. 2007 prescription drug state legislation. www.ncsl.org/programs/health/drugbill07.htm. March 19, 2009.
39 National Conference of State Legislatures. 2008 prescription drug state legislation. www.ncsl.org/programs/health/drugbill08.htm. March 19, 2009.
40 National Conference of State Legislatures. Condition-specific drug substitution legislation: epilepsy. www.ncsl.org/programs/health/Rx-substitution08.htm. March 19, 2009.
41 Crawford P, Feely M, Guberman A, et al. Are there potential problems with generic substitution of antiepileptic drugs? A review of issues. Seizure. 2006;15:165-76. [pmid: 16504545].
42 Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. Chapters available at: www.effectivehealthcare.ahrq.gov.
43 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
44 Follman D, Elliot P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45:769-73. [pmid: 1619456].
45 Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of intervention. Posted February 2008. Updated February 2008. Version 5.0.0. www.cochrane-handbook.org.
46 Schunemann H, Brozek J, Oxman A, et al. GRADE handbook for grading quality of evidence and strength of recommendation. The GRADE Working Group. 2008. [pmid: 18483053].
47 Reinikainen KJ, Keranen T, Halonen T, et al. Comparison of oxcarbazepine and carbamazepine: a double-blind study. Epilepsy Res. 1987;1:284-9. [pmid: 3504404].
48 Danner R, Partanen J, Keranen T, et al. Comparison of the effects of carbamazepine and oxcarbazepine on peripheral nerve conduction. Epilepsy Res. 1988;2:272-5. [pmid: 3197697].
49 Dam M, Ekberg R, Loyning Y, et al. A double-blind study comparing oxcarbazepine and carbamazepine in patients with newly diagnosed, previously untreated epilepsy. Epilepsy Res. 1989;3:70-6. [pmid: 2645120].
50 Sachdeo R, Kramer LD, Rosenberg A, et al. Felbamate monotherapy: controlled trial in patients with partial onset seizures. Ann Neurol. 1992;32:386-92. [pmid: 1416808].
51 Faught E, Sachdeo RC, Remler MP, et al. Felbamate monotherapy for partial-onset seizures: an active-control trial. Neurology. 1993;43:688-92. [pmid: 8469323].
52 Brodie MJ, Richens A, Yuen AW. Double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy. UK Lamotrigine/Carbamazepine Monotherapy Trial Group. Lancet. 1995;345:476-9. [pmid: 7710545].
53 Kalviainen R, Aikia M, Saukkonen AM, et al. Vigabatrin vs carbamazepine monotherapy in patients with newly diagnosed epilepsy. A randomized, controlled study. Arch Neurol. 1995;52:989-96. [pmid: 7575227].
54 Sabers A, Moller A, Dam M, et al. Cognitive function and anticonvulsant therapy: effect of monotherapy in epilepsy. Acta Neurol Scand. 1995;92:19-27. [pmid: 7572056].
55 Reunanen M, Dam M, Yuen AW. A randomised open multicentre comparative trial of lamotrigine and carbamazepine as monotherapy in patients with newly diagnosed or recurrent epilepsy. Epilepsy Res. 1996;23:149-55. [pmid: 8964276].
56 Tanganelli P, Regesta G. Vigabatrin vs. carbamazepine monotherapy in newly diagnosed focal epilepsy: a randomized response conditional cross-over study. Epilepsy Res. 1996;25:257-62. [pmid: 8956924].
57 Bill PA, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in adults with previously untreated epilepsy. Epilepsy Res. 1997;27:195-204. [pmid: 9237054].
58 Christe W, Kramer G, Vigonius U, et al. A double-blind controlled clinical trial: oxcarbazepine versus sodium valproate in adults with newly diagnosed epilepsy. Epilepsy Res. 1997;26:451-60. [pmid: 9127726].
59 Guerreiro MM, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in children and adolescents with epilepsy. Epilepsy Res. 1997;27:205-13. [pmid: 9237055].
60 Chadwick DW, Anhut H, Greiner MJ, et al. A double-blind trial of gabapentin monotherapy for newly diagnosed partial seizures. International Gabapentin Monotherapy Study Group 945-77. Neurology. 1998;51:1282-8. [pmid: 9818846].
61 Brodie MJ, Mumford JP. Double-blind substitution of vigabatrin and valproate in carbamazepine-resistant partial epilepsy. 012 Study group. Epilepsy Res. 1999;34:199-205. [pmid: 10210035].
62 Brodie MJ, Overstall PW, Giorgi L. Multicentre, double-blind, randomised comparison between lamotrigine and carbamazepine in elderly patients with newly diagnosed epilepsy. The UK Lamotrigine Elderly Study Group. Epilepsy Res. 1999;37:81-7. [pmid: 10515178].
63 Chadwick D. Safety and efficacy of vigabatrin and carbamazepine in newly diagnosed epilepsy: a multicentre randomised double-blind study. Vigabatrin European Monotherapy Study Group. Lancet. 1999;354:13-9. [pmid: 10406359].
64 Steiner TJ, Dellaportas CI, Findley LJ, et al. Lamotrigine monotherapy in newly diagnosed untreated epilepsy: a double-blind comparison with phenytoin. Epilepsia. 1999;40:601-7. [pmid: 10386529].
65 Aldenkamp AP, Baker G, Mulder OG, et al. A multicenter, randomized clinical study to evaluate the effect on cognitive function of topiramate compared with valproate as addon therapy to carbamazepine in patients with partial-onset seizures. Epilepsia. 2000;41:1167-78. [pmid: 10999556].
66 Dodrill CB, Arnett JL, Deaton R, et al. Tiagabine versus phenytoin and carbamazepine as add-on therapies: effects on abilities, adjustment, and mood. Epilepsy Res. 2000;42:123-32. [pmid: 11074185].
67 Gillham R, Kane K, Bryant-Comstock L, et al. A double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy with health-related quality of life as an outcome measure. Seizure. 2000;9:375-9. [pmid: 10985991].
68 Biton V, Mirza W, Montouris G, et al. Weight change associated with valproate and lamotrigine monotherapy in patients with epilepsy. Neurology. 2001;56:172-7. [pmid: 11160951].
69 Cramer J, Ryan J, Chang J, et al. The short-term impact of adjunctive tiagabine on health-related quality of life. Epilepsia. 2001;42:70-5. [pmid: 11520329].
70 Nieto-Barrera M, Brozmanova M, Capovilla G, et al. A comparison of monotherapy with lamotrigine or carbamazepine in patients with newly diagnosed partial epilepsy. Epilepsy Res. 2001;46:145-55. [pmid: 11463516].
71 Sackellares JC, Kwong WJ, Vuong A, et al. Lamotrigine monotherapy improves health-related quality of life in epilepsy: A double-blind comparison with valproate. Epilepsy & Behavior. 2002;3:376-82. [pmid: 12609336].
72 Biton V, Levisohn P, Hoyler S, et al. Lamotrigine versus valproate monotherapy-associated weight change in adolescents with epilepsy: results from a post hoc analysis of a randomized, double-blind clinical trial. J Child Neurol. 2003;18:133-9. [pmid: 12693782].
73 Meador KJ, Loring DW, Hulihan JF, et al. Differential cognitive and behavioral effects of topiramate and valproate. Neurology. 2003;60:1483-8. [pmid: 12743236].
74 Privitera MD, Brodie MJ, Mattson RH, et al. Topiramate, carbamazepine and valproate monotherapy: double-blind comparison in newly diagnosed epilepsy. Acta Neurol Scand. 2003;107:165-75. [pmid: 12614309].
75 Coppola G, Auricchio G, Federico R, et al. Lamotrigine versus valproic acid as first-line monotherapy in newly diagnosed typical absence seizures: an open-label, randomized, parallel-group study. Epilepsia. 2004;45:1049-53. [pmid: 15329068].
76 Fakhoury TA, Hammer AE, Vuong A, et al. Efficacy and tolerability of conversion to monotherapy with lamotrigine compared with valproate and carbamazepine in patients with epilepsy. Epilepsy Behav. 2004;5:532-8. [pmid: 15256191].
77 Wheless JW, Neto W, Wang S, et al. Topiramate, carbamazepine, and valproate monotherapy: double-blind comparison in children with newly diagnosed epilepsy. J Child Neurol. 2004;19:135-41. [pmid: 15072107].
78 Rowan AJ, Ramsay RE, Collins JF, et al. New onset geriatric epilepsy: a randomized study of gabapentin, lamotrigine, and carbamazepine. Neurology. 2005;64:1868-73. [pmid: 15955935].
79 Sobaniec W, Kulak W, Strzelecka J, et al. A comparative study of vigabatrin vs. carbamazepine in monotherapy of newly diagnosed partial seizures in children. Pharmacol Rep. 2005;57:646-53. [pmid: 16227648].
80 Steinhoff BJ, Ueberall MA, Siemes H, et al. The LAM-SAFE Study: lamotrigine versus carbamazepine or valproic acid in newly diagnosed focal and generalised epilepsies in adolescents and adults. Seizure. 2005;14:597-605. [pmid: 16278088].
81 Brodie MJ, Perucca E, Ryvlin P, et al. Comparison of levetiracetam and controlled-release carbamazepine in newly diagnosed epilepsy. Neurology. 2007;68:402-8. [pmid: 17283312].
82 Donati F, Gobbi G, Campistol J, et al. The cognitive effects of oxcarbazepine versus carbamazepine or valproate in newly diagnosed children with partial seizures. Seizure. 2007;16:670-9. [pmid: 17574448].
83 Kang HC, Eun BL, Wu Lee C, et al. The effects on cognitive function and behavioral problems of topiramate compared to carbamazepine as monotherapy for children with benign rolandic epilepsy. Epilepsia. 2007;48:1716-23. [pmid: 17561952].
84 Levisohn PM, Holland KD. Topiramate or valproate in patients with juvenile myoclonic epilepsy: a randomized open-label comparison. Epilepsy Behav. 2007;10:547-52. [pmid: 17482520].
85 Marson AG, Appleton R, Baker GA, et al. A randomised controlled trial examining the longer-term outcomes of standard versus new antiepileptic drugs. The SANAD trial. Health Technol Assess. iv. ix. 2007;11:iii-x. 1. 134. [pmid: 17903391].
86 Saetre E, Perucca E, Isojarvi J, et al. An international multicenter randomized double-blind controlled trial of lamotrigine and sustained-release carbamazepine in the treatment of newly diagnosed epilepsy in the elderly. Epilepsia. 2007;48:1292-302. [pmid: 17561956].
87 Stephen LJ, Sills GJ, Leach JP, et al. Sodium valproate versus lamotrigine: a randomised comparison of efficacy, tolerability and effects on circulating androgenic hormones in newly diagnosed epilepsy. Epilepsy Res. 2007;75:122-9. [pmid: 17553671].
88 Morrell MJ, Hayes FJ, Sluss PM, et al. Hyperandrogenism, ovulatory dysfunction, and polycystic ovary syndrome with valproate versus lamotrigine. Ann Neurol. 2008;64:200-11. [pmid: 18756476].
89 Glauser TA, Cnaan A, Shinnar S, et al. Ethosuximide, valproic acid, and lamotrigine in childhood absence epilepsy. N Engl J Med. 2010;362:790-9. [pmid: 20200383].
90 Ramsay E, Faught E, Krumholz A, et al. Efficacy, tolerability, and safety of rapid initiation of topiramate versus phenytoin in patients with new-onset epilepsy: A randomized double-blind clinical trial. Epilepsia. 2010. July. [Ebup ahead of print]. [pmid: 20633037].
91 Cumbo E, Ligori LD. Levetiracetam, lamotrigine, and phenobarbital in patients with epileptic seizures and Alzheimer's disease. Epilepsy Behav. 2010;17:461-6. [pmid: 20188634].
92 Sun W, Wang Y, Wang W, et al. Attention changes in epilepsy patients following 3-month topiramate or valproate treatment revealed by event-related potential. Int J Psychophysiol. 2008;68:235-41. [pmid: 18378030].
93 Edwards KR, Sackellares C, Vuong A, et al. Lamotrigine monotherapy improves depressive symptoms in epilepsy: a double-blind comparison with valproate. Epilepsy & Behavior. 2001;2:28-36. [pmid: 12609179].
94 Kwan P, Yip FP, Hui AC, et al. Effects of valproate or lamotrigine monotherapy on the reproductive endocrine and insulin-related metabolic profile in Chinese adults with epilepsy: a prospective randomized study. Epilepsy Behav. 2009;14:610-6. [pmid: 19435587].
95 Clemens B, Menes A, Nagy Z. Objective assessment of neurotoxicity while shifting from carbamazepine to oxcarbazepine. Acta Neurol Scand. 2004;109:324-9. [pmid: 15080858].
96 Arif H, Buchsbaum R, Pierro J, et al. Comparative Effectiveness of 10 Antiepileptic Drugs in Older Adults with. Epilepsy Arch Neurol. 2010;67:408-15. [pmid: 20385905].
97 Arif H, Buchsbaum R, Weintraub D, et al. Patient-reported cognitive side effects of antiepileptic drugs: predictors and comparison of all commonly used antiepileptic drugs. Epilepsy Behav. 2009;14:202-9. [pmid: 19010446].
98 Gobbi G, Pini A, Bertani G, et al. Prospective study of first-line vigabatrin monotherapy in childhood partial epilepsies. Epilepsy Res. 1999;35:29-37. [pmid: 10232792].
99 Kwan P, Brodie MJ. Effectiveness of first antiepileptic drug. Epilepsia. 2001;42:1255-60. [pmid: 11737159].
100 Babayigit A, Dirik E, Bober E, et al. Adverse effects of antiepileptic drugs on bone mineral density. Pediatr Neurol. 2006;35:177-81. [pmid: 16939856].
101 Kim SH, Lee JW, Choi KG, et al. A 6-month longitudinal study of bone mineral density with antiepileptic drug monotherapy. Epilepsy Behav. 2007;10:291-5. [pmid: 17224308].
102 Pack AM, Morrell MJ, Randall A, et al. Bone health in young women with epilepsy after one year of antiepileptic drug monotherapy. Neurology. 2008;70:1586-93. [pmid: 18443309].
103 Perry S, Holt P, Benatar M. Levetiracetam versus carbamazepine monotherapy for partial epilepsy in children less than 16 years of age. J Child Neurol. 2008;23:515-9. [pmid: 18182645].
104 Kim JM, Kwon S, Seo HE, et al. Long-term effectiveness and tolerability of topiramate in children with epilepsy under the age of 2 years: 4-year follow-up. J Korean Med Sci. 2009;24:1078-82. [pmid: 19949663].
105 Ma MS, Ding YX, Ying W, et al. Effectiveness of the first antiepileptic drug in the treatment of pediatric epilepsy. Pediatr Neurol. 2009;41:22-6. [pmid: 19520269].
106 de Araujo Filho GM, Pascalicchio TF, Lin K, et al. Neuropsychiatric profiles of patients with juvenile myoclonic epilepsy treated with valproate or topiramate. Epilepsy Behav. 2006;8:606-9. [pmid: 16504593].
107 Kauko K, Tammisto P. Comparison of two generically equivalent carbamazepine preparations. Ann Clin Res. suppl 11. 1974;6:21-5. [pmid: 4851115].
108 Glende M, Huller H, Mai I, et al. Comparative bioavailability of two carbamazepine tablets. Int J Clin Pharmacol Ther Toxicol. 1983;21:631-3. [pmid: 6668101].
109 Jumao-as A, Bella I, Craig B, et al. Comparison of steady-state blood levels of two carbamazepine formulations. Epilepsia. 1989;30:67-70. [pmid: 2912719].
110 Hartley R, Aleksandrowicz J, Ng PC, et al. Breakthrough seizures with generic carbamazepine: a consequence of poorer bioavailability?. Br J Clin Pract. 1990;44:270-3. [pmid: 2206824].
111 Hartley R, Aleksandrowicz J, Bowmer CJ, et al. Dissolution and relative bioavailability of two carbamazepine preparations for children with epilepsy. J Pharm Pharmacol. 1991;43:117-9. [pmid: 1672895].
112 Oles KS, Penry JK, Smith LD, et al. Therapeutic bioequivalency study of brand name versus generic carbamazepine. Neurology. 1992;42:1147-53. [pmid: 1603340].
113 Reunanen M, Heinonen EH, Nyman L, et al. Comparative bioavailability of carbamazepine from two slow-release preparations. Epilepsy Res. 1992;11:61-6. [pmid: 1563339].
114 Silpakit O, Amornpichetkoon M, Kaojarern S. Comparative study of bioavailability and clinical efficacy of carbamazepine in epileptic patients. Ann Pharmacother. 1997;31:548-52. [pmid: 9161646].
115 Aldenkamp AP, Rentmeester T, Hulsman J, et al. Pharmacokinetics and cognitive effects of carbamazepine formulations with different dissolution rates. Eur J Clin Pharmacol. 1998;54:185-92. [pmid: 9626926].
116 Nielsen KA, Dahl M, Tommerup E, et al. Comparative daily profiles with different preparations of lamotrigine: a pilot investigation. Epilepsy Behav. 2008;13:127-30. [pmid: 18406211].
117 Lund L. Clinical significance of generic inequivalence of three different pharmaceutical preparations of phenytoin. Eur J Clin Pharmacol. 1974;7:119-24. [pmid: 4851052].
118 Chen SS, Allen J, Oxley J, et al. Comparative bioavailability of phenytoin from generic formulations in the United Kingdom. Epilepsia. 1982;23:149-52. [pmid: 7075570].
119 Hodges S, Forsythe WI, Gillies D, et al. Bioavailability and dissolution of three phenytoin preparations for children. Dev Med Child Neurol. 1986;28:708-12. [pmid: 3817309].
120 Kishore K, Jailakhani BL, Sharma JN, et al. Serum phenytoin levels with different brands. Indian J Physiol Pharmacol. 1986;30:171-6. [pmid: 3546122].
121 Mikati M, Bassett N, Schachter S. Double-blind randomized study comparing brand-name and generic phenytoin monotherapy. Epilepsia. 1992;33:359-65. [pmid: 1547767].
122 Soryal I, Richens A. Bioavailability and dissolution of proprietary and generic formulations of phenytoin. J Neurol Neurosurg Psychiatry. 1992;55:688-91. [pmid: 1527539].
123 Vadney VJ, Kraushaar KW. Effects of switching from Depakene to generic valproic acid on individuals with mental retardation. Ment Retard. 1997;35:468-72. [pmid: 9425876].
124 Borst SI, Lockwood CH. Plasma level studies on different brands of sodium diphenylhydantoin (DPH) and primidone. Int J Clin Pharmacol Biopharm. 1975;12:309-14. [pmid: 1242131].
125 Tsai JJ, Lai ML, Yang YH, et al. Comparison on bioequivalence of four phenytoin preparations in patients with multiple-dose treatment. J Clin Pharmacol. 1992;32:272-6. [pmid: 1564132].
126 Zachry WM 3rd, Doan QD, Clewell JD, et al. Case-control analysis of ambulance, emergency room, or inpatient hospital events for epilepsy and antiepileptic drug formulation changes. Epilepsia. 2009;50:493-500. [pmid: 18616554].
127 Rascati KL, Richards KM, Johnsrud MT, et al. Effects of antiepileptic drug substitutions on epileptic events requiring acute care. Pharmacotherapy. 2009;29:769-74. [pmid: 19558250].
128 Devine ST, Barron J, Behm A. Acute epilepsy exacerbations in patients switched between A-rated anti-epileptic drugs. Curr Med Res Opin. 2010;26:455-63. [pmid: 20014974].
129 Labiner D, Paradis PE, Manjunath R, et al. Generic antiepileptic drugs and associated medical resource utilization in the United States. Neurology. 2010;74:1566-74. [pmid: 20393142].
130 Garnett WR, Gilbert TD, O'Connor P. Patterns of care, outcomes, and direct health plan costs of antiepileptic therapy: a pharmacoeconomic analysis of the available carbamazepine formulations. Clin Ther. 2005;27:1092-103. [pmid: 16154489].
131 Andermann F, Duh MS, Gosselin A, et al. Compulsory generic switching of antiepileptic drugs: high switchback rates to branded compounds compared with other drug classes. Epilepsia. 2007;48:464-9. [pmid: 17346246].
132 Duh MS, Paradis PE, Latremouille-Viau D, et al. The risks and costs of multiple-generic substitution of topiramate. Neurology. 2009;72:2122-9. [pmid: 19528520].
133 Paradis PE, Latremouille-Viau D, Moore Y, et al. Projected economic impact of clinical findings of generic entry of topiramate on G4 European countries. Curr Med Res Opin. 2009;25:1793-805. [pmid: 19505202].
134 Crawford P, Hall WW, Chappell B, et al. Generic prescribing for epilepsy. Is it safe?. Seizure. 1996;5:1-5. [pmid: 8777549].
135 Wilner AN. Therapeutic equivalency of generic antiepileptic drugs: results of a survey. Epilepsy Behav. 2004;5:995-8. [pmid: 15582850].
136 Berg MJ, Gross RA, Tomaszewski KJ, et al. Generic substitution in the treatment of epilepsy: case evidence of breakthrough seizures. Neurology. 2008;71:525-30. [pmid: 18695164].
137 Jain KK. Investigation and management of loss of efficacy of an antiepileptic medication using carbamazepine as an example. J R Soc Med. 1993;86:133-6. [pmid: 8459373].
138 Smith B, Zachry WI. Aed Generic Substitution - the Effects on the Dependent Variable in Epilepsy Clinical Trials. Epilepsia. 2009;50:113.
139 Burkhardt RT, Leppik IE, Blesi K, et al. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology. 2004;63:1494-6. [pmid: 15505173].
140 Goodwin M. The importance of brand continuity in epilepsy drugs. Nurs Times. 2005;101:26-7. [pmid: 15997944].
141 Papsdorf TB, Ablah E, Ram S, et al. Patient perception of generic antiepileptic drugs in the Midwestern United States. Epilepsy Behav. 2009;14:150-3. [pmid: 18845274].
142 Czapinski P, Czapinska E. Clinical effect of a switch from an original to a generic agent in drug-resistant epilepsy-prospective study. Epilepsia. 2009;50:111.
143 Karakis I, Montouris GD. Adverse outcomes of generic substitution of antiepileptic drugs in a tertiary epilepsy center. Epilepsia. 2009;50:94-5.
144 Malsin LS, Sandok E, Stojic A. Generic switchback rate of antiepileptic medications in persons with epilepsy. Epilepsia. 2009;50:264.
145 McAuley JW, Chen AY, Elliott JO, et al. An assessment of patient and pharmacist knowledge of and attitudes toward reporting adverse drug events due to formulation switching in patients with epilepsy. Epilepsy Behav. 2009;14:113-7. [pmid: 18768168].
146 Koch G, Allen JP. Untoward effects of generic carbamazepine therapy. Arch Neurol. 1987;44:578-9. [pmid: 3579673].
147 Sachdeo RC, Belendiuk G. Generic versus branded carbamazepine. Lancet. 1987;1:1432. [pmid: 2884519].
148 Welty TE, Pickering PR, Hale BC, et al. Loss of seizure control associated with generic substitution of carbamazepine. Ann Pharmacother. 1992;26:775-7. [pmid: 1611158].
149 Gilman JT, Alvarez LA, Duchowny M. Carbamazepine toxicity resulting from generic substitution. Neurology. 1993;43:2696-7. [pmid: 8255480].
150 Di Bonaventura C, Fattouch J, Fabbrini G, et al. Switching from branded to generic antiepileptic drugs as a confounding factor and unpredictable diagnostic pitfall in epilepsy management. Epileptic Disord. 2007;9:465-6. [pmid: 18055310].
151 Sarco DP, Riviello JJ, Takeoka M. Difference in tolerability between generic and brand name gabapentin formulations for treatment of pediatric epilepsy. Epilepsia. 2005;46:201.
152 Makus KG, McCormick J. Substituting generic lamotrigine for brandname lamotrigine (Lamictal (R)) in patients with epilepsy: An observational assessment of outcomes in Canada. Epilepsia. 2006;47:194.
153 Stefan H, Pawlowski M, Kerling F, et al. Use of generic preparations of lamotrigine: Interim analysis of an ongoing prospective study at the epilepsy centre, Erlangen. Epilepsia. 2007;48:42.
154 Fitzgerald C, Jacobson MP. Generic substitution of levetiracetam resulting in increased incidence of breakthrough seizures. Epilepsia. 2009;50:93. [pmid: 19298435].
155 Cook AM, Bensalem-Owen MK, Owens-Acey TT, et al. Pharmacokinetic variations and impact on seizures after brand to generic substitution of oxcarbazepine in adults with epilepsy. Epilepsia. 2009;50:111.
156 Czapinski P, Czapinska E. Oxcarbazepine (OXC) in epilepsy: Efficacy of a generic drug. Epilepsia. 2007;48:113.
157 Hagemann G, Fuchs M, Zinke J, et al. Seizure count while switching back and forth between branded and generic oxcarbazepine. Epilepsia. 2009;50:111.
158 Wyllie E, Pippenger CE, Rothner AD. Increased seizure frequency with generic primidone. JAMA. 1987;258:1216-7. [pmid: 3626006].
159 Rosenbaum DH, Rowan AJ, Tuchman L, et al. Comparative bioavailability of a generic phenytoin and Dilantin. Epilepsia. 1994;35:656-60. [pmid: 8026413].
160 MacDonald JT. Breakthrough seizure following substitution of Depakene capsules (Abbott) with a generic product. Neurology. 1987;37:1885. [pmid: 3120036].
161 Dhanaraj M, Jayavelu A. Non-equivalence of bioavailability between generic and branded form of sodium valproate. Neurol India. 2004;52:398. [pmid: 15472447].
162 Duh MS, Andermann F, Paradis PE, et al. The economic consequences of generic substitution for antiepileptic drugs in a public payer setting: the case of lamotrigine. Dis Manage. 2007;10:216-25. [pmid: 17718660].
163 Saetre E, Abdelnoor M, Perucca E, et al. Antiepileptic drugs and quality of life in the elderly: results from a randomized double-blind trial of carbamazepine and lamotrigine in patients with onset of epilepsy in old age. Epilepsy & behavior: E&B. 2010;17:395-401. [pmid: 20149756].
164 Helmstaedter C, Witt JA. Cognitive outcome of antiepileptic treatment with levetiracetam versus carbamazepine monotherapy: a non-interventional surveillance trial. Epilepsy Behav. 2010;18:74-80. [pmid: 20462801].
165 Kesselheim AS, Stedman MR, Bubrick EJ, et al. Seizure outcomes following the use of generic versus brand-name antiepileptic drugs. Drugs. 2010;70:605-21. [pmid: 20329806].
166 Patorno E, Bohn RL, Wahl PM, et al. Anticonvulsant medications and the risk of suicide, attempted suicide, or violent death. JAMA. 2010;303:1401-9. [pmid: 20388896].
167 Lee SA, Lee HW, Heo K, et al. Cognitive and behavioral effects of lamotrigine and carbamazepine monotherapy in patients with newly diagnosed or untreated partial epilepsy. Seizure. 2011;20:49-54. [pmid: 21067945].
168 Zheleznova EV, Kalinin VV, Zemlyanaya AA, et al. Monotherapy of epilepsy in women: psychiatric and neuroendocrine aspects. Neurosci Behav Physiol. 2010;40:157-62. [pmid: 20033304].