# Peer Reviewers

Maria Summa, Pharm.D., BCPS

Associate Professor of Pharmacy Practice and Administration

Saint Joseph College School of Pharmacy

Hartford, CT

Kimford Meador, M.D.

Director

Emory Epilepsy Center

Professor of Neurology

Emory University

Atlanta, GA

Scott Devine, M.P.H., Ph.D.

Outcomes Research Scientist, Merck

Assistant Professor

Saint Louis University Center for Outcomes Research

Saint Louis University

Saint Louis, MO

Robert Gumnit, M.D.

Neurologist

MINCEP Epilepsy Care

Minneapolis, MN

Peer reviewer comments on a preliminary draft of this report were considered by the Evidence-based Practice Center in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.