# Methods

## Topic Refinement

The topic for this report was nominated via a public process. The Evidence-based Practice Center (EPC) drafted a topic refinement document with proposed Key Questions and solicited input from a panel of key informants on the questions and scope of the report. The public was then invited to comment on the topic refinement document and Key Questions. After a review of the public commentary, the Key Questions were finalized by the EPC and approved by the Agency for Healthcare Research and Quality (AHRQ).

## Literature Search Strategy

Two independent investigators conducted systematic literature searches of MEDLINE (from 1950 to the March 23, 2011), Web of Science, the Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews from the earliest possible date through March 23, 2011. For the older versus newer antiepileptic medication search, we utilized Cochrane's Highly Sensitive Search Strategy (Sensitivity Maximizing Version 2008) to limit the search to randomized controlled trials and the Scottish Intercollegiate Guidelines Network Observational Study Search Filter to limit the search to observational studies. The search for the innovator versus generic evaluation contained no search filters, but had to be a direct comparison of an antiepileptic medication versus another version of the same medication (innovator versus its generic, or for health care utilization, a generic to innovator, innovator to generic, or generic to generic comparison). We did not limit the search to “A” rated versions of products. No language restriction was imposed in either search and a manual search of references from reports of clinical trials or review articles was also conducted.

Detailed search strategies are provided in Appendix A.

## Study Selection

Studies were included in the evaluation of key questions if they: (1) compared older antiepileptic medications (phenytoin, carbamazepine, valproic acid, clonazepam, phenobarbital, ethosuximimide, primidone) to newer antiepileptic medications or compared innovator antiepileptic medications to generic antiepileptic medications (or in the case of health care utilization, compared generic to innovator, innovator to generic, or generic to generic version of the same medication); (2) conducted in patients with epilepsy; and (3) reported data on prespecified clinical or humanistic outcomes.

## Data Abstraction

Through the use of a standardized data abstraction tool, two reviewers independently collected data, with disagreement resolved through discussion. The data extraction tools are available in Appendix B. The following information was obtained from each study, where applicable: author identification, year of publication, source of study funding, study design characteristics and methodological quality criteria, study population (including study inclusion and exclusion criteria, run-in period, study withdrawals, antiepileptic medication utilized, length of study, and duration of patient followup), patient baseline characteristics (gender, age, ethnicity), patient pharmacogenetic profile, seizure etiology (partial, generalized, specific epilepsy syndrome), seizure type (new onset, chronic disease), types of antiepileptic medication (individual drug names, drug class and Biopharmaceutics Classification System [BCS] class), comorbidities, and use of concurrent standard medical therapies. Intermediate and final health and harms outcomes were collected where applicable. Authors were contacted for clarification or to provide additional data, where applicable.

We differentiate the outcomes for evaluation based on the following schemes in Table 5 and Table 6.

Table 5 Outcomes for innovator and generic antiepileptic evaluation

Pharmacokinetics | Comparative Efficacy | General Measures of Tolerance and Harms
Maximum concentration(Cmax) Minimum concentration (Cmin) Average steady-state concentration (Css) Area under the curve (AUC) Time to maximum concentration (Tmax) | Seizure frequency Incidence of breakthrough seizure Incidence of status epilepticus Dose needed to control seizures after switching from an innovator antiepileptic to its generic counterpart Secondary seizure injury; fracture, laceration, head trauma, aspiration pneumonia Incidence of breakthrough seizure | Incidence of adverse events Incidence of individual adverse events Incidence of adverse events resulting in therapy withdrawal Incidence of adverse events not resulting in therapy withdrawal Skin rash Neurologic adverse events Suicidal Ideation Mortality Medical service utilization; office/emergency department visits, hospitalizations Hypotension Hospital stay duration Loss of driver's license Loss of employment Rates of switching from generic antiepileptic back to its innovator counterpart for any reason

AUC = Area under the curve; Cmax = Maximum concentration; Cmin = Minimum concentration; Css = Average steady-state concentration; Tmax = Time to maximum concentration

Table 6 Outcomes for older and newer antiepileptic evaluation

Comparative Efficacy | General Measures of Tolerance and Harms
Time to first seizure Time to study exit due to lack of efficacy Proportion of seizure-free patients Proportion of patients completing the study Proportion of patients achieving seizure remission Seizure frequency | Proportion of patients withdrawn due to adverse events Cosmetic adverse events Incidence of adverse events Incidence of individual adverse events Incidence of adverse events resulting in therapy withdrawal Incidence of adverse events not resulting in therapy withdrawal Skin rash Neurologic adverse events Suicidal Ideation Mortality Medical service utilization: office/emergency department visits, hospitalizations, ambulance use

## Validity Assessment

Validity assessment was performed using the recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.42 Studies were given an overall score of good, fair, or poor (Table 7). This rating system does not attempt to assess the comparative validity across different types of study design. For example, a “fair” RCT was not judged to have the same methodological quality as a “fair” observational study. Both study design and quality rating were considered when interpreting the methodological quality of a study.

Table 7 Summary ratings of quality of individual studies

Quality Rating | Definition
Good (low risk of bias) | These studies have the least bias, and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality include the following: a formal randomized, controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20% dropout; and clear reporting of dropouts.
Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

## Literature Synthesis

In the evaluation of older versus newer antiepileptic medications, each newer antiepileptic medication was compared with an individual older epileptic medication as part of a direct comparative study. In the evaluation of innovator and generic medications, each innovator antiepileptic drug was compared with its corresponding generic medication separately as part of a direct comparative study. Comparative trials or studies could be qualitatively described or quantitatively synthesized while single-arm observational studies, case series, or case reports were termed descriptive studies.

## Quantitative Analysis

Controlled clinical trials could be crossover or parallel trials but may or may not be randomized. Controlled observational studies were cohort or case-control studies and had to have a control group. Controlled clinical trials and controlled observational studies could be pooled separately, but clinical trials and observational studies could not be pooled together.

When pooling continuous endpoints, a weighted mean difference along with 95 percent confidence intervals (CI) were calculated using a DerSimonian and Laird random effects model.43 In order to pool data of different AEDs together for continuous endpoints, we used an inverse variance weighting approach as standardized mean difference (mean difference between treatment and control groups divided by pooled standard deviation) and 95 percent CIs. In cases where mean change scores from baseline for each group were not reported, we calculated the difference between the mean baseline and mean followup scores for each group. Standard deviations (SDs) of the change scores were calculated from the SD of the baseline values and of the followup values, using the formula: SD_baseline-followup_=sqrt(SD^2^_baseline_ + SD^2^_followup_ – 2*(correlation coefficient)SD_baseline_*SD_followup_). A correlation coefficient of 0.5 proposed by Follman and colleagues was used.44 In the event where there was more than one treatment group versus control, each treatment group was treated as a separate trial for meta-analysis, dividing the control group sample size by the number of treatment arms.

For dichotomous endpoints, weighted averages were reported as relative risks (RRs) with associated 95 percent CIs. As heterogeneity between included studies is expected, a DerSimonian and Laird random-effects model was used when pooling data and calculating RRs and 95 percent CIs.

Statistical heterogeneity was assessed using the I^2^ statistic which assesses the degree of inconsistency not due to chance across studies and ranges from 0 to100 percent with values of >50 percent representing important statistical heterogeneity, respectively. Egger's weighted regression statistics were used to assess for the presence of publication bias.

Statistical analysis was performed using StatsDirect statistical software, version 2.7.8 (StatsDirect Ltd, Cheshire, England). A p-value of <0.05 was considered statistically significant for all analyses.45

For the section on medical service utilization, data were available as incidence rate ratios in the individual observational studies and were described but not pooled.

## Subgroup and Sensitivity Analyses

To assess the effect of heterogeneity on our meta-analysis conclusions, subgroup and sensitivity analyses were conducted. In both the older versus newer and innovator versus generic evaluations, we performed subgroup analyses based on gender, ethnicity, patient age, and patient pharmacogenetic profile.

In subgroup analyses for the older versus newer evaluation, we evaluated the results in those with new onset versus chronic (refractory) disease and by seizure type (partial, generalized, and specific epilepsy syndrome), gender, and age. In subgroup analyses for the innovator versus generic evaluation, innovator medications were specifically studied against known “A” rated generics, and innovator medications within a BCS class (I, II, or III) were compared with their corresponding generic medications within that same class.

## Grading the Strength of Evidence

We used the EPC methodology for grading, which is based on the criteria and methods of GRADE (Grading of Recommendations Assessment, Development) to assess the strength of evidence. This system uses four required domains: risk of bias, consistency, directness, and precision.46 Additional domains will not be utilized because they are deemed not relevant to this review. All assessments will be made by two investigators (with disagreements resolved through discussion). The evidence pertaining to each Key Question will be classified into three broad categories: (1) “high,” (2) “moderate,” (3) or “low” grade (Table 8). If the evidence is too sparse, a grade of insufficient was assigned. Below we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report.

Table 8 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect

### Risk of Bias

Risk of bias is the degree to which the included studies for any given outcome or comparison has a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations. For study design, whether the study was a randomized controlled trial or an observational study was recorded. Studies were also ranked as no limitations, serious limitations, or very serious limitations. Because all of the included studies were randomized controlled trials with few limitations, they were considered to have a low risk of bias.

### Consistency

Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. This was assessed in two main ways: (1) the effect sizes had the same sign, in that they were on the same side of unity; (2) the range of effect sizes was narrow. We ranked this domain as no inconsistency, serious inconsistency, and very serious inconsistency. For outcomes whereby only a single study was included, consistency was not judged. We also considered measures of heterogeneity from our meta-analyses in evaluating consistency.

### Directness

Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most important health outcomes. We ranked this domain as no indirectness, serious indirectness, and very serious indirectness.

### Precision

Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. For example, when a meta-analysis was performed, we evaluated the confidence interval around the summary effect size. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g., both clinically important superiority and inferiority), a circumstance that will preclude a conclusion.

## Rating Applicability

Trials had to meet five of the following seven criteria in order to be considered an effectiveness trial: used a primary care population, used less stringent eligibility criteria, assessed final health outcomes, had adequate study duration with clinically relevant treatment modalities, assessed adverse events, had an adequate sample size, and used intention-to-treat analysis. Those meeting fewer than five criteria were classified as efficacy trials and deemed to have less applicability.

The factors that are important for determining the applicability of a study to clinical practice are evaluated based on the patient population enrolled, the intervention given, the evaluation of a comparator, the types of outcomes evaluated and the setting where care was administered. The factors used to evaluate the applicability of a study to clinical practice are further defined in Table 9; those factors that were extracted into evidence tables for every study included in the report. By using all of the applicable studies to answer a Key Question, the applicability of the body of evidence was then determined and reported separately and qualitatively for each outcome of interest.

Table 9 Applicability PICOTS and data to extract

Feature | Condition That Limits Applicability | Features to be Extracted Into Evidence Table
Population | Differences between patients in the study and the community | Eligibility criteria, demographics
Population | Events rates markedly different than in the community | Event rates in treatment and control groups
Intervention | Treatment not reflective of current practice | Type of device, device name
Comparator | Use of substandard alternative therapy | Type of comparator
Outcomes | Intermediate end points, brief followup periods, improper definitions for outcomes, composite end points, lack of adverse event reporting | Outcomes (benefits and harms) and how they were defined
Settings | Settings where standards of care differ markedly from setting of interest | Clinical setting and geographic setting

PICOTS = Population, Intervention, Comparator, Outcomes, Settings

## Peer Review and Public Commentary

A draft of this Evidence Report was sent to peer reviewers, the representatives of the AHRQ and the scientific review committee at Oregon Health and Science University. The draft report and posted to the Effective Health Care Web site for public comment. In response to the comments of the peer reviewers and the public, revisions were made to the Evidence Report, and a summary of the comments and their disposition was submitted to AHRQ.