# Future Research

## Limitations of Current Research

This comparative effectiveness review (CER) is limited by heterogeneity. A heterogenous group of antiepileptic medications was placed into groups based on whether they were older, newer, innovator, or generic. A heterogenous group of epilepsy types was also lumped together, and the diagnosis and detection of these different types have changed over time, making clear subgroup evaluations using these trials difficult. Patients with different pharmacodynamic and pharmacokinetic genetic polymorphisms were not elucidated in virtually all the trials, but these factors could lead some medications to be more or less preferable. The use of studies from different countries, different time periods, utilizing differing study durations, mixing of patients with different baseline seizure frequency rates and different environmental triggers, and the use of “A” rated and non-“A” rated products in some analyses may have also introduced heterogeneity.

While there are some important differences between agents within the older and newer groups, we do not believe that the differences between groups are too marked to allow pooling. The drugs in our CER are all used to control or reduce seizure frequency, work in the central nervous system to cause their effect, and are all given via the same route of adminstration, and many share aspects of their mechanism of action (for example sodium channel or glutamate/glutyl-amino-butyric-acid effects) in a broad sense. We evaluate some of the major potential sources of heterogenetiy in subgroup analyses. Other sources of heterogeneity, such as genomic differences, durations of therapy, and mixing of patients with differing seizure frequencies should have been attenuated within a trial due to randomization. We are transparent in our presentation of the results since in the full report we provide individual agent comparisons and subgroup analyses for other potential sources of heterogeneity but could not report the results in the executive summary given wording limitations.

We did not include every possible endpoint of interest. We had to make some choices as to what endpoints would be included and which would not, and we wanted to make those decisions a priori. We included myriad endpoints that while not exhaustive, are very broad but may not contain a specific endpoint that a particular practitioner may wish to see. For instance, we included loss of job or driving privileges but did not include school performance.

While we sought to evaluate the impact of newer versus older antiepileptic medications, only a few older antiepileptic medications were substantively evaluated and were compared to a greater or lesser extent with newer antiepileptic medications. In the full report, we provide the data for each individual newer antiepileptic medication versus each individual older antiepileptic medication. This data is more specific than the aggregate pooled data of all newer antiepileptic medication versus each older antiepileptic medication and decreases the clinical and methodological heterogeneity in the data. However, the power to detect differences in these individual analyses is substantially compromised.

For the older versus newer antiepileptic medication evaluation, no controlled trials or observational studies evaluated the impact of older or newer antiepileptic medications on the use of medical services including office or emergency room visits, ambulance services, outpatient medical care, or hospitalization.

Our evaluation of newer versus older antiepileptic medications provide populationwide insight into comparative benefits and harms but cannot account for individual patient factors that may make the use of a certain antiepileptic medication more or less desirable. Factors such as pregnancy or desire to become pregnant within a specified period of time, concomitant drugs and risk of serious drug interactions, and genetic polymorphisms or the ethnicities most likely to harbor polymorphisms that increase the risk of severe skin rashes can be used to select an optimal therapeutic choice for an individual patient. We need more information on the benefits and harms associated with older and newer antiepileptic medications in different seizure types and it needs to be understood that the classification of epilepsy types is an evolving science.

For the innovator versus generic medication evaluation, seizure occurrence and frequency, pharmacokinetics, and tolerability of innovator antiepileptic medications are similar to that of their generic counterparts. Since these trials were predominantly crossover of parallel design trials, they can only provide information on the innate comparability of the products when used in a population of patients with epilepsy. They cannot be used to say that switching from one version to another would or would not result in a loss of efficacy or an increase in patient harm.

Controlled observational studies show that switchback rates from generic to innovator products are high and that there may be an increased use of medical services associated with switching from one version (either an innovator or generic) of an antiepileptic medication to another version (either an innovator or generic). Unfortunately, these observational studies, while well conducted, have inherent biases and limitations that reduce their internal validity.

Our subgroup analyses could have been very important in helping identify which populations have an accentuated or attenuated effect versus the average, but due to a lack of power and methodological limitations, we were unable to generate data that could guide therapy in this manner.

For the innovator versus generic medication evaluation, no controlled clinical trials or observational studies evaluated the impact on mortality, health-related quality of life, loss of driver's license or employment, time to first seizure, seizure remission, seizure freedom for the duration of the study, secondary seizure injury, status epilepticus or the dose requirements required for seizure control.

## Future Avenues for Research

For the newer versus older comparison, future direct comparative clinical trials of the same size and duration can continue to increase power to detect differences, if they truly exist. This is especially true for individual newer versus individual older antiepileptic medication comparisons. More extensive determination of harms and more clearly delineating the population being studied would also be beneficial. More extensive evaluations of medical service utilization in controlled clinical trials and observational studies are also warranted.

Whether “A” rated versions of innovator and generic medications provide similar seizure control, pharmacokinetics, and tolerability in a large population is not as important as conducting randomized, controlled trials directed at determining whether patients switched from one “A” rated version of a medication to another “A” rated version have alterations in intermediate and final health outcomes versus continuing on their original antiepileptic medication. If so, the reasons (pharmacokinetic, psychological, other) for differential effects need to be researched. A proposed methodology would be to take a population of patients receiving either innovator or an “A” rated generic version of a medication and then randomize some patients to be switched and other patients to be maintained on initial therapy in a double blind manner. This would eliminate the impact of clinician or patient apprehension about the switch to impact resource utilization or to increase the risk of experiencing a seizure or an adverse event either directly or indirectly through noncompliance or dose alteration. Followup could be relatively brief (3 months) and should include a pharmacokinetic (using Bayesian population pharmacokinetics whereby only one or two samples from each patient would suffice) and final health outcome component (assessing for seizure occurrence, seizure frequency, health care utilization, and adverse events). Without randomization, blinding, and exclusive use of “A” rated products, future studies would share the substantial flaws of the current body of literature.

Future research for the brand versus generic evaluation should included controlled clinical trials and observational studies of increased duration to capture endpoints such as seizure remission, seizure freedom for the duration of the study and mortality. Additionally, future research should be designed to capture and report outcomes such as loss of driver's license or employment, secondary seizure injury, status epilepticus and health-related quality of life.

Future newer versus older and innovator versus generic antiepileptic medication trials should report on their benefits and harms in these subpopulations even in the absence of power to judge significance because it will allow subsequent systematic reviewer to pool the results together.

Endpoints such as bone fracture and concussion should be assessed in everyone, loss of job or driving privileges should be assessed in adults, and school performance should be evaluated in children.