# Forest Plots of Meta-analysis of Efficacy and Safety Endpoints

Figure J-1 Composite forest plot of meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial

This figure depicts the meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 1.06 with 95 percent confidence interval of 0.57 to 1.97. The second trial by Rowan and colleague in 2005 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.36 to 1.55. The combined effect of the two trials showed a relative risk of 0.92 with 95 percent confidence interval of 0.57 to 1.48. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleague in 2007 provided relative risk of 0.67 with 96 percent confidence interval of 0.33 to 1.34. The second trial by Rowan and colleague in 2005 provided relative risk of 0.53 with 95 percent confidence interval of 0.23 to 1.19. The third trial by Fakhoury and colleague in 2004 provided a relative risk of 2.36 with a 95 percent confidence interval of 0.22 to 26.14. The fourth trial by Brodie and colleague in 1999 provided a relative risk of 0.01 with a 95 percent confidence interval of 0.009 to 1.04. The fifth and sixth trial by Reunanen and colleague in 1996 provided a relative risk of 1.53 and 1.59 with a 95 percent confidence interval of 0.3 to 18.56 and 0.13 to 19.22, respectively. The combined effect of the six trials showed a relative risk of 0.63 with 95 percent confidence interval of 0.37 to 1.04. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.50 with 95 percent confidence interval of 0.19 to 1.27. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.94 with 95 percent confidence interval of 0.50 to 1.78. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 2.01 with 95 percent confidence interval of 0.26 to 15.27. The combined effect of all newer AEDs showed a relative risk of 0.75 with 95 percent confidence interval of 0.51 to 1.12. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.63 with 95 percent confidence interval of 0.34 to 1.18, trials having patients with chronic epilepsy showed a relative risk of 2.36 with 95 percent confidence interval of 0.22 to 26.14, trials having greater than 90 percent males showed a relative risk of 0.64 with 95 percent confidence interval of 0.33 to 1.23, and trials having patients 65 years or older showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 1.04.

Figure J-2 Composite forest plot of meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. A single trial with lamotrigine as the newer agent by Steiner and colleague in 1999 provided a relative risk of 0.22 with 95 percent confidence interval of 0.02 to 2.41. A single trial with oxcarbazepine as the newer agent by Bill and colleague in 1997 provided a relative risk of 0.20 with 95 percent confidence interval of 0.02 to 2.22. A single trial with topiramate as the newer agent by Ramsay and colleague in 2010 provided a relative risk of 0.96 with 95 percent confidence interval of 0.06 to 16.60. The combined effect of all newer AEDs showed a relative risk of 0.30 with 95 percent confidence interval of 0.05 to 1.95. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.21 with 95 percent confidence interval of 0.02 to 1.79.

Figure J-3 Composite forest plot of meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs=antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleague in 2007 provided relative risk of 1.00 with 95 percent confidence interval of 0.28 to 3.60. The second trial by Fakhoury and colleague in 2004 provided a relative risk of 1.52 with a 95 percent confidence interval of 0.13 to 18.42. The combined effect of the two trials showed a relative risk of 1.06 with 95 percent confidence interval of 0.30 to 3.76. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.75 with 95 percent confidence interval of 0.19 to 2.95. A single trial with vigabatrin as the newer agent by Brodie and colleague in 1999 provided a relative risk of 0.99 with 95 percent confidence interval of 0.06 to 17.08. The combined effect of all newer AEDs showed a relative risk of 0.94 with 95 percent confidence interval of 0.31 to 2.80. In the subgroup analysis, trials having patients with chronic epilepsy showed a relative risk of 1.28 with 95 percent confidence interval of 0.11 to 15.14.

Figure J-4 Composite forest plot of meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. A single trial with gabapentin as the newer agent by Marson and colleague in 2007 provided a relative risk of 1.35 with 95 percent confidence interval of 1.14 to 1.60. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleague in 2007 provided relative risk of 1.23 with 96 percent confidence interval of 1.04 to 1.45. The second and third trial by Reunanen and colleague in 1996 provided a relative risk of 0.80 and 0.90 with a 95 percent confidence interval of 0.50 to 1.40 and 0.50 to 1.60, respectively. The fourth trial by Brodie and colleague in 1995 provided relative risk of 0.80 with 95 percent confidence interval of 0.60 to 1.20. The combined effect of the four lamotrigine trials showed a relative risk of 0.97 with 95 percent confidence interval of 0.73 to 1.28. A single trial with oxcarbazepine as the newer agent by Marson and colleague in 2007 provided a relative risk of 1.06 with 95 percent confidence interval of 0.84 to 1.33. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 1.05 with 95 percent confidence interval of 0.89 to 1.25. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 1.79 with 95 percent confidence interval of 1.33 to 2.40. The combined effect of all newer AEDs showed a relative risk of 1.14 with 95 percent confidence interval of 0.98 to 1.33. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.79 with 95 percent confidence interval of 1.33 to 2.40, and trials having patients with new onset epilepsy showed a relative risk of 1.20 with 95 percent confidence interval of 0.55 to 2.65.

Figure J-5 Composite forest plot of meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. A single trial with lamotrigine as the newer agent by Steiner and colleague in 1999 provided a relative risk of 1.40 with 95 percent confidence interval of 0.80 to 2.30. A single trial with topiramate as the newer agent by Ramsay and colleague in 2010 provided a relative risk of 2.00 with 95 percent confidence interval of 0.98 to 4.12. The combined effect of both newer AEDs showed a relative risk of 1.59 with 95 percent confidence interval of 1.04 to 2.43. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.00 with 95 percent confidence interval of 0.50 to 2.20, trials having patients with generalized epilepsy showed a relative risk of 1.50 with 95 percent confidence interval of 0.70 to 3.20, and trials having patients with new onset epilepsy showed a relative risk of 1.40 with 95 percent confidence interval of 0.80 to 2.30.

Figure J-6 Composite forest plot of meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of time to first seizure in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. A single trial with lamotrigine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.71 with 95 percent confidence interval of 0.57 to 0.88. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.91 with 95 percent confidence interval of 0.73 to 1.14. The combined effect of both newer AEDs showed a relative risk of 0.80 with 95 percent confidence interval of 0.63 to 1.02.

Figure J-7 Composite forest plot of meta-analysis of seizure occurrence in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of seizure occurence in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamzepine trials, the first and second trial by Aldenkamp and colleague in 1998 provided a relative risk 0.26 and 0.26 with 95 percent confidence interval of 0.02 to 3.27 and 0.02 to 3.27, respectively. The third, fourth and fifth trial by Silpakit and colleague in 1997 provided relative risk of 0.40, 1.40, and 0.60 with 95 percent confidence interval of 0.08 to 2.21, 0.44 to 5.88 and 0.14 to 2.94, respectively. The sixth trial by Oles and colleague in 1992 provided a relative risk of 0.50 with 95 percent confidence interval of 0.11 to 2.09. The seventh trial by Hartley and colleague in 1990 provided a relative risk of 1.00 with 95 percent confidence interval of 0.46 to 2.19. The eighth trial by Jumao-as and colleague in 1989 provided a relative risk of 1.00 with 95 percent confidence interval of 0.47 to 2.14. The combined effect of the carbamazepine trials showed a relative risk of 0.86 with 95 percent confidence interval of 0.55 to 1.32. In the phenytoin trials, the first, second and third trial by Kishore and colleague in 1986 provided a relative risk of 0.40 with 95 percent confidence interval of 0.08 to 2.17. The combined effect of phenytoin trials showed a relative risk of 0.40 with 95 percent confidence interval of 0.14 to 1.12. A single valproic acid trial by Vadney and colleague in 1997 provided a relative risk of 1.05 with 95 percent confidence interval of 0.65 to 1.70. The combined effect of carbamazepine, phenytoin and valproic acid trials showed a relative risk of 0.87 with 95 percent confidence interval of 0.64 to 1.18. In the subgroup analysis, trials with BCS Class I agents showed a relative risk of 1.05 with 95 percent confidence interval of 0.65 to 1.70, trials with BCS Class II agents showed a relative risk of 0.76 with 95 percent confidence interval of 0.51 to 1.14, and trials with only A-rated antiepileptics showed a relative risk of 0.50 with 95 percent confidence interval of 0.10 to 2.43.

Figure J-8 Composite forest plot of meta-analysis of seizure frequency in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of seizure frequency in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamzepine trials, the first trial by Oles and colleague in 1992 provided a mean difference in seizure frequency of 0.03 with 95 percent confidence interval of -0.08 to 0.14. The second trial by Jumao-as and colleague in 1989 provided a mean difference in seizure frequency of -1.20 with 95 percent confidence interval of -11.02 to 8.62. The combined effect of the carbamazepine trials showed a mean difference in seizure frequency of 0.03 with 95 percent confidence interval of -0.08 to 0.14. A single valproic acid trial by Vadney and colleague in 1997 provided a mean difference in seizure frequency of -1.06 with 95 percent confidence interval of -16.05 to 13.93. The combined effect of carbamazepine and valproic acid trials showed a mean difference in seizure frequency of 0.03 with 95 percent confidence interval of -0.08 to 0.14. In the subgroup analysis, trials with BCS Class I agents showed a mean difference in seizure frequency of -1.06 with 95 percent confidence interval of -16.05 to 13.93, trials with BCS Class II agents showed a mean difference in seizure frequency of 0.03 with 95 percent confidence interval of -0.08 to 0.14, and trials with only A-rated antiepileptics showed a mean difference in seizure frequency of 0.03 with 95 percent confidence interval of -0.08 to 0.14.

Figure J-9 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 1.10 with 95 percent confidence interval of 0.99 to 1.23. The second trial by Rowan and colleague in 2005 provided a relative risk of 0.79 with a 95 percent confidence interval of 0.66 to 0.94. The third, fourth and fifth trials by Chadwick and colleague in 1998 provided a relative risk of 1.18, 0.96 and 0.98 with 95 percent confidence interval of 0.89 to 1.74, 0.70 to 1.44 and 0.72 to 1.46, respectively. The combined effect of the gabapentin trials showed a relative risk of 0.99 with 95 percent confidence interval of 0.83 to 1.17. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 0.87 with 95 percent confidence interval of 0.76 to 0.98. The second trial by Rowan and colleague in 2005 provided a relative risk of 0.69 with 95 percent confidence interval of 0.57 to 0.83. The third trial by Steinhoff and colleague in 2005 provided a relative risk of 0.83 with 95 percent confidence interval of 0.53 to 1.30. The fourth trial by Fakhoury and colleague in 2004 provided a relative risk of 1.27 with a 95 percent confidence interval of 0.60 to 2.82. The fifth trial by Nieto-Barrera and colleague in 2001 provided a relative risk of 0.83 with 95 percent confidence interval of 0.60 to 1.15. The sixth trial by Brodie and colleague in 1999 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.34 to 0.74. The seventh trial by Brodie and colleague in 1995 provided a relative risk of 0.72 with 95 percent confidence interval of 0.53 to 0.96. The eighth and ninth trial by Reunanen and colleague in 1996 provided a relative risk of 0.81 and 0.36 with a 95 percent confidence interval of 0.46 to 1.44 and 0.18 to 0.75, respectively. The combined effect of the lamotrigine trials showed a relative risk of 0.74 with 95 percent confidence interval of 0.64 to 0.86. A single trial with oxcarbazepine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.93 with 95 percent confidence interval of 0.80 to 1.07. In the trials with topiramate as the newer agent, the first trial by Kang and colleague in 2007 provided a relative risk of 1.10 with 95 percent confidence interval of 0.55 to 2.23. The second trial by Marson and colleague in 2007 provided a relative risk of 1.07 with 95 percent confidence interval of 0.96 to 1.20. The third and fourth trials by Privitera and colleague in 2003 provided a relative risk of 0.98 and 1.07 with 95 percent confidence interval of 0.73 to 1.36 and 0.80 to 1.50. The combinded effect of the topiramate trials showed a relative risk of 1.06 with 95 percent confidence interval of 0.96 to 1.17. In the trials with vigabatrin as the newer agent, the first trial by Sobaniec and colleague in 2005 provided a relative risk of 9.68 with 95 percent confidence interval of 1.00 to 99.39. The second trial by Chadwick and colleague in 1999 provided a relative risk of 1.01 with 95 percent confidence interval of 0.82 to 1.26. The third trial by Kalviainen and colleague in 1995 provided a relative risk of 1.00 with 95 percent confidence interval of 0.62 to 1.62. The combined effect of all vigabatrin trials showed a relative risk of 1.03 with 95 percent confidence interval of 0.79 to 1.36. The combined effect of all newer AEDs showed a relative risk of 0.90 with 95 percent confidence interval of 0.82 to 1.00. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.99 with 95 percent confidence interval of 0.81 to 1.22, trials having patients with new onset epilepsy showed a relative risk of 0.84 with 95 percent confidence interval of 0.73 to 0.97, trials having patients with chronic epilepsy showed a relative risk of 2.22 with 95 percent confidence interval of 0.36 to 13.79, trials having greater than 90 percent males showed a relative risk of 0.74 with 95 percent confidence interval of 0.64 to 0.86, trials having children 18 years or younger showed a relative risk of 1.09 with 95 percent confidence interval of 0.60 to 1.99, and trials having patients 65 years or older showed a relative risk of 0.51 with 95 percent confidence interval of 0.37 to 0.71.

Figure J-10 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational trials. In the trials with lamtorigine as the newer agent, the first trial by Kim and colleage in 2007 provided relative risk of 1.24 with 95 percent confidence interval of 0.07 to 20.32. The second trial by Kwan and colleague in 2001 provided a relative risk of 0.66 with 95 percent confidence interval of 0.48 to 0.87. The combined effect of the lamotrigine trials showed a relative risk of 0.66 with 95 percent confidence interval of 0.49 to 0.89. A single trial with levetiracetam as the newer agent by Perry and colleage in 2008 provided a relative risk of 1.67 with 95 percent confidence interval of 0.73 to 4.35. A single trial with topiramate as the newer agent by Kim and colleague in 2009 provided a relative risk of 0.89 with 95 percent confidence interval of 0.74 to 1.05. A single trial with vigabatrin as the newer agent by Gobbi and colleague in 1999 provided a relative risk of 20.52 with 95 percent confidence interval of 2.22 to 202.53. The combined effect of all newer AEDs showed a relative risk of 0.93 with 95 percent confidence interval of 0.61 to 1.40. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 4.33 with 95 percent confidence interval of 0.31 to 59.98, trials having patients with new onset epilepsy showed a relative risk of 1.47 with 95 percent confidence interval of 0.46 to 4.72, and trials having children 18 years or younger showed a relative risk of 1.82 with 95 percent confidence interval of 0.48 to 6.91.

Figure J-11 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with controlled or sustained release carbamazepine in controlled clinical trials

AEDs=antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to controlled or sustained release carbamazepine in controlled clinical trials. A single tiral of lamotrigine as the newer agent by Saetre and colleague in 2007 provided a relative risk of 0.82 with 95 percent confidence interval of 0.52 to 1.27. A single trial with levetiracetam as the newer agent by Brodie and colleage in 2007 provided a relative risk of 1.00 with 95 percent confidence interval of 0.79 to 1.26. The combined effect of all newer AEDs showed a relative risk of 0.96 with 95 percent confidence interval of 0.78 to 1.18. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.96 with 95 percent confidence interval of 0.78 to 1.18, and trials having patients 65 years or older showed a relative risk of 0.82 with 95 percent confidence interval of 0.52 to 1.27.

Figure J-12 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. A single trial with lamotrigine as the newer agent by Steiner and colleage in 1999 provided a relative risk of 0.99 with 95 percent confidence interval of 0.75 to 1.13. In the trials with oxcarbazepine as the newer agent, the first trial by Bill and colleague in 1997 provided a relative risk of 0.92 with 95 percent confidence interval of 0.70 to 1.22. The second trial by Guerreiro and colleague in 1997 provided a relative risk of 0.70 with 95 percent confidence interval of 0.45 to 1.08. The combinded effect of the oxcarbazepine trials showed a relative risk of 0.85 with 95 percent confidence interval of 0.66 to 1.09. The combined effect of all newer AEDs showed a relative risk of 0.91 with 95 percent confidence interval of 0.76 to 1.09. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.91 with 95 percent confidence interval of 0.76 to 1.09, and trials having children 18 years or younger showed a relative risk of 0.70 with 95 percent confidence interval of 0.45 to 1.08.

Figure J-13 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs=antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. A single trial with felbamate as the newer agent by Sachedo and colleague in 1992 provided a relative risk of 1.00 with 95 percent confidence interval of 0.11 to 9.24. In the trials with lamtorigine as the newer agent, the first trial by Glauser and colleage in 2010 provided relative risk of 1.20 with 95 percent confidence interval of 0.64 to 2.27. The second trial by Kwan and colleague in 2009 provided a relative risk of 0.67 with 95 percent confidence interval of 0.33 to 1.30. The third trial by Morrell and colleague in 2008 provided a relative risk of 0.96 with 95 percent confidence interval of 0.69 to 1.33. The fourth trial by Marson and colleagues in 2007 provided a relative risk of 0.91 with a 95 percent confidence interval of 0.78 to 1.07. The fifth trial by Stephen and colleague in 2007 provided a relative risk of 0.76 with 95 percent confidence interval of 0.56 to 1.03. The sixth trial by Steinhoff and colleague in 2005 provided a relative risk of 1.14 with a 95 percent confidence interval of 0.36 to 3.64. The seventh trial by Coppola in colleague in 2004 provided a relative risk of 2.00 with 95 percent confidence interval of 0.64 to 6.60. The eighth trial by Fakhoury and colleague in 2004 provided a relative risk of 0.88 with 95 percent confidence interval of 0.54 to 1.50. The ninth trial by Biton and colleague in 2003 provided a relative risk of 0.56 with a 95 percent confidence interval of 0.17 to 1.73. The tenth trials by Biton and colleague in 2001 provided a relative risk of 0.66 with 95 percent confidence interval of 0.41 to 1.04. The combined effect of the lamotrigine trials showed a relative risk of 0.88 with 95 percent confidence interval of 0.78 to 0.99. A single trial with oxcarbazepine as the newer agent by Christie and colleage in 1997 provided a relative risk of 1.20 with 95 percent confidence interval of 0.87 to 1.66. In the trials with topiramate as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 1.09 with 95 percent confidence interval of 0.95 to 1.26. The second trial by Meador and colleague in 2003 provided a relative risk of 1.49 with 95 percent confidence interval of 0.52 to 4.44. The third and fourth trials by Privitera and colleague in 2003 provided a relative risk of 0.79 and 0.87 with 95 percent confidence interval of 0.59 to 1.12 and 0.65 to 1.23. The fifth trial by Aldenkamp and colleague in 2000 provided a relative risk of 2.07 with 95 percent confidence interval of 0.74 to 5.96. The combined effect of the topiramate trials showed a relative risk of 0.98 with 95 percent confidence interval of 0.80 to 1.21. A single trial with vigabatrin as the newer agent by Brodie and colleague in 1999 provided a relative risk of 0.68 with 95 percent confidence interval of 0.42 to 1.08. The combined effect of all newer AEDs showed a relative risk of 0.96 with 95 percent confidence interval of 0.85 to 1.09. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.05 with 95 percent confidence interval of 0.57 to 1.92, trials having patients with generlized epilepsy showed a relative risk of 1.30 with 95 percent confidence interval of 0.78 to 2.18, trials having patients with new onset epilepsy showed a relative risk of 1.03 with 95 percent confidence interval of 0.77 to 1.38, trials having patients with chronic epilepsy showed a relative risk of 0.82 with 95 percent confidence interval of 0.59 to 1.13, trials having children 18 years or younger showed a relative risk of 1.34 with 95 percent confidence interval of 0.76 to 2.37, and trials having greater than 90 percent females showed a relative risk of 0.96 with 95 percent confidence interval of 0.69 to 1.33.

Figure J-14 Composite forest plot of meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of overall withdrawal in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational trials. In the trials with lamtorigine as the newer agent, the first trial by Kim and colleage in 2007 provided relative risk of 1.82 with 95 percent confidence interval of 0.11 to 30.02. The second trial by Kwan and colleague in 2001 provided a relative risk of 0.90 with 95 percent confidence interval of 0.63 to 1.29. The combined effect of the lamotrigine trials which is also the combined effect of all newer AEDs showed a relative risk of 0.91 with 95 percent confidence interval of 0.63 to 1.30. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.91 with 95 percent confidence interval of 0.63 to 1.30.

Figure J-15 Composite forest plot of meta-analysis of withdrawals for any reason in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system; RCTs = randomized controlled trials

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal for any reason in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamzepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a relative risk 1.00 and 1.00 with 95 percent confidence interval of 0.04 to 24.53 and 0.04 to 24.53, respectively. The third and fourth trial by Oles and colleague in 1992 provided relative risk of 0.20 and 1.50 with 95 percent confidence interval of 0.02 to 2.06 and 0.33 to 7.00, respectively. The fifth trial by Reunanen and colleague in 1992 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.94. The sixth trial by Hartley and colleague in 1991 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.71. The seventh trial by Hartley and colleague in 1990 provided a relative risk of 0.33 with 95 percent confidence interval of 0.03 to 3.87. The eighth trial by Jumao-as and colleague in 1989 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.00. The ninth trial by Glende and colleague in 1983 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.00. The combined effect of the carbamazepine trials showed a relative risk of 0.85 with 95 percent confidence interval of 0.30 to 2.40. A single carbamazepine observational trial by Garnett and colleague in 2005 provided a relative risk of 1.17 with 95 percent confidence interval of 1.04 to 1.31. In the phenytoin trials, the first trial by Mikati and colleague in 1992 provided a relative risk of 1.00 with 95 percent confidence interval of 0.20 to 4.94. The second, third and fourth trial by Kishore and colleague in 1986 provided a relative risk of 1.00 with 95 percent confidence interval of 0.03 to 32.24. The fifth trial by Lund and colleague in 1974 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.53. The combined effect of phenytoin trials showed a relative risk of 1.00 with 95 percent confidence interval of 0.24 to 4.14. The combined effect of carbamazepine and phenytoin controlled trials showed a relative risk of 0.90 with 95 percent confidence interval of 0.39 to 2.08. The combined effect of carbamazepine and phenytoin observational trials showed a relative risk of 1.17 with 95 percent confidence interval of 1.04 to 1.31. In the subgroup analysis, controlled trials with BCS Class II agents showed a relative risk of 0.90 with 95 percent confidence interval of 0.39 to 2.08, observational trials with BCS Class II agents showed a relative risk of 1.17 with 95 percent confidence interval of 1.04 to 1.31 and trials with only A-rated antiepileptics showed a relative risk of 0.80 with 95 percent confidence interval of 0.12 to 5.16.

Figure J-16 Composite forest plot of meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs=antiepileptic drugs, FE=focalized epilepsy

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 2.32 with 95 percent confidence interval of 1.67 to 3.22. The second trial by Rowan and colleague in 2005 provided a relative risk of 1.63 with a 95 percent confidence interval of 0.57 to 4.65. The combined effect of the gabapentin trials showed a relative risk of 2.52 with 95 percent confidence interval of 1.64 to 3.08. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 1.40 with 95 percent confidence interval of 0.97 to 2.01. The second trial by Rowan and colleague in 2005 provided a relative risk of 2.18 with 95 percent confidence interval of 0.81 to 5.92. The third trial by Steinhoff and colleague in 2005 provided a relative risk of 3.00 with 95 percent confidence interval of 0.25 to 36.30. The fourth and fifth trial by Reunanen and colleague in 1996 provided a relative risk of 1.53 and 0.53 with a 95 percent confidence interval of 0.13 to 18.56 and 0.03 to 9.12, respectively. The sixth trial by Brodie and colleague in 1999 provided a relative risk of 0.47 with a 95 percent confidence interval of 0.03 to 8.15. The seventh trial by Brodie and colleague in 1995 provided a relative risk of 0.99 with 95 percent confidence interval of 0.23 to 4.20. The combined effect of the lamotrigine trials showed a relative risk of 1.43 with 95 percent confidence interval of 1.03 to 1.99. In the trials with oxcarbazepine as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 1.01 with 95 percent confidence interval of 0.63 to 1.60. The second trials by Dam and colleague in 1989 provided a relative risk of 1.07 with 95 percent confidence interval of 0.19 to 5.94. The combined effect of the oxcarbazepine trials showed a relative risk of 1.01 with 95 percent confidence interval of 0.64 to 1.59. In the trials with topiramate as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 1.29 with 95 percent confidence interval of 0.89 to 1.87. The second and third trials by Privitera and colleague in 2003 provided a relative risk of 1.38 and 1.14 with 95 percent confidence interval of 0.58 to 3.43 and 0.47 to 2.89. The combinded effect of the topiramate trials showed a relative risk of 1.28 with 95 percent confidence interval of 0.93 to 1.78. In the trials with vigabatrin as the newer agent, the first trial by Chadwick and colleague in 1999 provided a relative risk of 2.57 with 95 percent confidence interval of 1.24 to 5.35. The second trial by Kalviainen and colleague in 1995 provided a relative risk of 4.33 with 95 percent confidence interval of 1.44 to 13.63. The combined effect of all vigabatrin trials showed a relative risk of 2.98 with 95 percent confidence interval of 1.58 to 5.61. The combined effect of all newer AEDs showed a relative risk of 1.59 with 95 percent confidence interval of 1.25 to 2.02. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 2.54 with 95 percent confidence interval of 1.22 to 5.27, trials having patients with new onset epilepsy showed a relative risk of 2.31 with 95 percent confidence interval of 1.41 to 3.78, trials having greater than 90 percent males showed a relative risk of 1.89 with 95 percent confidence interval of 0.72 to 5.00, and trials having patients 65 years or older showed a relative risk of 0.47 with 95 percent confidence interval of 0.01 to 23.49.

Figure J-17 Composite forest plot of meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational trials. In the trials with lamtorigine as the newer agent, the first trial by Kim and colleage in 2007 provided relative risk of 1.24 with 95 percent confidence interval of 0.07 to 20.32. The second trial by Kwan and colleague in 2001 provided a relative risk of 1.03 with 95 percent confidence interval of 0.65 to 1.57. The combined effect of the lamotrigine trials showed a relative risk of 1.03 with 95 percent confidence interval of 0.66 to 1.60. In the trials with topiramate as the newer agent, the first trial by Kim and colleague in 2009 provided a relative risk of 0.53 with 95 percent confidence interval of 0.22 to 1.22. The second trial by Ma and colleague in 2009 provided a relative risk of 1.00 with 95 percent confidence interval of 0.59 to 1.69. The combined effect of the topiramate trials showed a relative risk of 0.81 tih 95 percent confidence interval of 0.45 to 1.45. A single trial with vigabatrin as the newer agent by Gobbi and colleague in 1999 provided a relative risk of 18.36 with 95 percent confidence interval of 1.97 to182.09. The combined effect of all newer AEDs showed a relative risk of 0.97 with 95 percent confidence interval of 0.60 to 1.56. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 18.36 with 95 percent confidence interval of 1.97 to 182.09, trials having patients with new onset epilepsy showed a relative risk of 0.97 with 95 percent confidence interval of 0.60 to 1.56, and trials having children 18 years or younger showed a relative risk of 1.08 with 95 percent confidence interval of 0.37 to 3.15.

Figure J-18 Composite forest plot of meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. A single trial with lamotrigine as the newer agent by Steiner and colleage in 1999 provided a relative risk of 0.55 with 95 percent confidence interval of 0.07 to 4.15. In the trials with oxcarbazepine as the newer agent, the first trial by Bill and colleague in 1997 provided a relative risk of 1.01 with 95 percent confidence interval of 0.11 to 9.59. The second trial by Guerreiro and colleague in 1997 provided a relative risk of 1.32 with 95 percent confidence interval of 0.34 to 5.16. The combinded effect of the oxcarbazepine trials showed a relative risk of 1.24 with 95 percent confidence interval of 0.34 to 4.55. The combined effect of all newer AEDs showed a relative risk of 1.03 with 95 percent confidence interval of 0.33 to 3.23. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 1.03 with 95 percent confidence interval of 0.33 to 3.23.

Figure J-19 Composite forest plot of meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs; GE = generalized epilepsy

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. In the trials with lamtorigine as the newer agent, the first trial by Kwan and colleague in 2009 provided a relative risk of 0.40 with 95 percent confidence interval of 0.03 to 4.67. The second trial by Morrell and colleague in 2008 provided a relative risk of 2.03 with 95 percent confidence interval of 0.27 to 15.41. The third trial by Marson and colleague in 2007 provided a relative risk of 2.53 with a 95 percent confidence interval of 1.59 to 4.06. The fourth trial by Stephen and colleague in 2007 provided a relative risk of 0.67 with 95 percent confidence interval of 0.33 to 1.35. The fifth trial by Steinhoff and colleague in 2005 provided a relative risk of 4.55 with a 95 percent confidence interval of 0.43 to 49.99. The sixth trial by Coppola in colleague in 2004 provided a relative risk of 2.00 with 95 percent confidence interval of 0.64 to 6.60. The combined effect of the lamotrigine trials showed a relative risk of 1.53 with 95 percent confidence interval of 0.74 to 3.71. A single trial with oxcarbazepine as the newer agent by Christie and colleage in 1997 provided a relative risk of 0.95 with 95 percent confidence interval of 0.33 to 2.71. In the trials with topiramate as the newer agent, the first trial by Levisohn and colleague in 2007 provided a relative risk of 2.44 with 95 percent confidence interval of 0.25 to 26.45. The second trial by Marson and colleague in 2007 provided a relative risk of 1.33 with 95 percent confidence interval of 0.79 to 2.27. The third and fourth trials by Privitera and colleague in 2003 provided a relative risk of 0.95 and 0.78 with 95 percent confidence interval of 0.40 to 2.44 and 0.32 to 2.05. The fifth trial by Aldenkamp and colleague in 2000 provided a relative risk of 0.34 with 95 percent confidence interval of 0.03 to 4.04. The combined effect of the topiramate trials showed a relative risk of 1.12 with 95 percent confidence interval of 0.74 to 1.70. A single trial with vigabatrin as the newer agent by Brodie and colleague in 1999 provided a relative risk of 0.57 with 95 percent confidence interval of 0.29 to 1.13. The combined effect of all newer AEDs showed a relative risk of 1.10 with 95 percent confidence interval of 0.77 to 1.56. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.56 with 95 percent confidence interval of 0.28 to 1.10, trials having patients with generlized epilepsy showed a relative risk of 2.28 with 95 percent confidence interval of 0.79 to 6.58, trials having patients with new onset epilepsy showed a relative risk of 0.98 with 95 percent confidence interval of 0.55 to 1.78, trials having patients with chronic epilepsy showed a relative risk of 0.56 with 95 percent confidence interval of 0.28 to 1.10, trials having children 18 years or younger showed a relative risk of 2.00 with 95 percent confidence interval of 0.64 to 6.60, and trials having greater than 90 percent females showed a relative risk of 2.03 with 95 percent confidence interval of 0.27 to 15.41.

Figure J-20 Composite forest plot of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational trials. In the trials with lamtorigine as the newer agent, the first trial by Kim and colleage in 2007 provided relative risk of 1.82 with 95 percent confidence interval of 0.11 to 30.02. The second trial by Kwan and colleague in 2001 provided a relative risk of 1.00 with 95 percent confidence interval of 0.60 to 1.63. The combined effect of the lamotrigine trials showed a relative risk of 0.91 with 95 percent confidence interval of 0.63 to 1.30. A single trial with topiramate as the newer agent by Ma and colleague in 2009 provided a relative risk of 1.02 with 95 percent confidence interval of 0.65 to 1.60. The combined effect of all newer AEDs showed a relative risk of 1.02 with 95 percent confidence interval of 0.73 to 1.42. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 1.02 with 95 percent confidence interval of 0.73 to 1.42 and trials having children 18 years or younger showed a relative risk of 1.02 with 95 percent confidence interval of 0.65 to 1.60.

Figure J-21 Composite forest plot of meta-analysis of withdrawals due to lack of efficacy in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs=antiepileptic drugs; BCS=biopharmaceutics classification system

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamzepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a relative risk 1.00 and 1.00 with 95 percent confidence interval of 0.04 to 24.53 and 0.04 to 24.53, respectively. The third and fourth trial by Oles and colleague in 1992 provided relative risk of 0.33 and 1.00 with 95 percent confidence interval of 0.03 to 3.84 and 0.19 to 5.29, respectively. The fifth trial by Reunanen and colleague in 1992 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.94. The sixth trial by Hartley and colleague in 1991 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.71. The seventh trial by Hartley and colleague in 1990 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.99. The eighth trial by Jumao-as and colleague in 1989 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.00. The ninth trial by Glende and colleague in 1983 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.00. The combined effect of the carbamazepine trials showed a relative risk of 0.87 with 95 percent confidence interval of 0.29 to 2.63. In the phenytoin trials, the first trial by Mikati and colleague in 1992 provided a relative risk of 2.00 with 95 percent confidence interval of 0.30 to 14.09. The second, third and fourth trial by Kishore and colleague in 1986 provided a relative risk of 1.00 with 95 percent confidence interval of 0.03 to 32.24. The fifth trial by Lund and colleague in 1974 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.53. The combined effect of phenytoin trials showed a relative risk of 1.45 with 95 percent confidence interval of 0.28 to 7.53. The combined effect of carbamazepine and phenytoin controlled trials showed a relative risk of 1.02 with 95 percent confidence interval of 0.41 to 2.54. In the subgroup analysis, controlled trials with BCS Class II agents showed a relative risk of 1.02 with 95 percent confidence interval of 0.41 to 2.54 and trials with only A-rated antiepileptics showed a relative risk of 0.75 with 95 percent confidence interval of 0.15 to 3.73.

Figure J-22 Composite forest plot of meta-analysis of twelve-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of twelve-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. A single trial with gabapentin as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.85 with 95 percent confidence interval of 0.76 to 0.95. A single trial with lamotrigine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.96 with 96 percent confidence interval of 0.87 to 1.06. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.48 with 95 percent confidence interval of 0.39 to 0.59. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.90 with 95 percent confidence interval of 0.81 to 0.99. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 0.95 with 95 percent confidence interval of 0.79 to 1.14. The combined effect of all newer AEDs showed a relative risk of 0.81 with 95 percent confidence interval of 0.67 to 0.99. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.95 with 95 percent confidence interval of 0.79 to 1.14.

Figure J-23 Composite forest plot of meta-analysis of 24-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of twenty-four-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. A single trial with gabapentin as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.79 with 95 percent confidence interval of 0.66 to 0.94. A single trial with lamotrigine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.92 with 96 percent confidence interval of 0.78 to 1.08. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.73 with 95 percent confidence interval of 0.58 to 0.91. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.84 with 95 percent confidence interval of 0.71 to 1.00. The combined effect of all newer AEDs showed a relative risk of 0.82 with 95 percent confidence interval of 0.72 to 0.94.

Figure J-24 Composite forest plot of meta-analysis of 12-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of twelve-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. A single trial with lamotrigine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.94 with 96 percent confidence interval of 0.84 to 1.04. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 1.00 with 95 percent confidence interval of 0.90 to 1.10. The combined effect of all newer AEDs showed a relative risk of 0.97 with 95 percent confidence interval of 0.89 to 1.06.

Figure J-25 Composite forest plot of meta-analysis of 24-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of twenty-four-month seizure remission in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. A single trial with lamotrigine as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.83 with 96 percent confidence interval of 0.68 to 1.00. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.88 with 95 percent confidence interval of 0.73 to 1.05. The combined effect of all newer AEDs showed a relative risk of 0.85 with 95 percent confidence interval of 0.73 to 1.00.

Figure J-26 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of seizure freedom in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. A single trial with gabapentin as the newer agent by Rowan and colleague in 2005 provided a relative risk of 0.74 with 95 percent confidence interval of 0.56 to 0.97. In the trials with lamtorigine as the newer agent, the first trial by Rowan and colleague in 2005 provided a relative risk of 0.80 with 95 percent confidence interval of 0.62 to 1.03. The second trial by Steinhoff and colleague in 2005 provided a relative risk of 0.86 with 95 percent confidence interval of 0.72 to 1.02. The third trial by Fakhoury and colleague in 2004 provided a relative risk of 1.31 with 95 percent confidence interval of 0.72 to 2.59. The fourth trial by Nieto-Barrera and colleague in 2001 provided a relative risk of 0.89 with a 95 percent confidence interval of 0.79 to 1.02. The fifth trial by Brodie and colleague in 1999 provided a relative risk of 1.88 with a 95 percent confidence interval of 1.07 to 3.49. The sixth and seventh trial by Reunanen and colleague in 1996 provided a relative risk of 0.94 and 1.10 with 95 percent confidence interval of 0.71 to 1.28 and 0.85 to 1.48. The eighth trial by Brodie and colleague in 1995 provided a relative risk of 0.90 with 95 percent confidence interval of 0.61 to 1.34. The combined effect of the lamotrigine trials showed a relative risk of 0.94 with 95 percent confidence interval of 0.83 to 1.05. In the trials with oxcarbazepine as the newer agent, the first trial by Donati and colleague in 2007 provided a relative risk of 1.25 with 95 percent confidence interval of 0.82 to 2.06. The second trial by Dam and colleague in 1989 provided a relative risk of 0.87 with 95 percent confidence interval of 0.66 to 1.14. The third trial by Danner and colleague in 1988 provided a relative risk of 0.96 with 95 percent confidence interval of 0.53 to 1.72. The combined effect of the oxcarbazepine trials showed a relative risk of 0.96 with 95 percent confidence interval of 0.77 to 1.19. In the trials with topiramate as the newer agent, the first trial by Kang and colleague in 2007 provided a relative risk of 0.99 with 95 percent confidence interval of 0.74 to 1.32. The second and third trials by Wheless and colleague in 2004 provided a relative risk of 1.61 and 1.51 with 95 percent confidence interval of 0.87 to 3.76 and 0.80 to 3.53. The fourth and fifth trials by Privitera and colleague in 2003 provided a relative risk of 1.12 and 1.01 with 95 percent confidence interval of 0.84 to 1.57 and 0.75 to 1.42. The combinded effect of the topiramate trials showed a relative risk of 1.08 with 95 percent confidence interval of 0.91 to 1.27. In the trials with vigabatrin as the newer agent, the first trial by Tanganelli and colleague in 1996 provided a relative risk of 0.82 with 95 percent confidence interval of 0.47 to 1.42. The second trial by Kalviainen and colleague in 1995 provided a relative risk of 0.62 with 95 percent confidence interval of 0.37 to 0.98. The combined effect of all vigabatrin trials showed a relative risk of 0.70 with 95 percent confidence interval of 0.49 to 1.01. The combined effect of all newer AEDs showed a relative risk of 0.94 with 95 percent confidence interval of 0.87 to 1.03. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.94 with 95 percent confidence interval of 0.84 to 1.05, trials having patients with generalized epilepsy showed a relative risk of 1.08 with 95 percent confidence interval of 0.90 to 1.29, trials having patients with new onset epilepsy showed a relative risk of 0.91 with 95 percent confidence interval of 0.77 to 1.09, trials having patients with chronic epilepsy showed a relative risk of 1.31 with 95 percent confidence interval of 0.72 to 2.59, trials having children 18 years or younger showed a relative risk of 0.99 with 95 percent confidence interval of 0.84 to 1.17, trials having patients between ages of 18 to 65 showed a relative risk of 0.82 with 95 percent confidence interval of 0.47 to 1.42, and trials having patients 65 years or older showed a relative risk of 1.88 with 95 percent confidence interval of 1.07 to 3.49.

Figure J-27 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of seizure freedom in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational trials. A single trial with lamotrigine as the newer agent by Kwan and colleague in 2001 provided a relative risk of 1.48 with 95 percent confidence interval of 1.16 to 1.87. Two trials with levetiracetam as the newer agent by Perry and colleague in 2008 and Helmestadter and colleagues in 2010 provided a relative risk of 1.07 with 95 percent confidence interval of 0.93 to 1.24. A single trial with oxcarbazepine as the newer agent by Sabers and colleague in 1995 provided a relative risk of 0.69 with 95 percent confidence interval of 0.31 to 1.37. A single trial with topiramate as the newer agent by Ma and colleague in 2009 provided a relative risk of 1.05 with 95 percent confidence interval of 0.87 to 1.29. A single trial with vigabatrin as the newer agent by Gobbi and colleague in 1999 provided a relative risk of 0.82 with 95 percent confidence interval of 0.58 to 1.13. The combined effect of all newer AEDs showed a relative risk of 1.75 with 95 percent confidence interval of 0.90 to 1.29. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.84 with 95 percent confidence interval of 0.62 to 1.16, trials having patients with new onset epilepsy showed a relative risk of 1.11 with 95 percent confidence interval of 0.84 to 1.47, and trials having children 18 years or younger showed a relative risk of 0.99 with 95 percent confidence interval of 0.84 to 1.17.

Figure J-28 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with controlled or sustained release carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of seizure freedom in patients with epilepsy taking newer antiepileptic drugs compared to controlled or sustained release carbamazepine in controlled clinical trials. A single tiral of lamotrigine as the newer agent by Saetre and colleague in 2007 provided a relative risk of 0.82 with 95 percent confidence interval of 0.64 to 1.03. A single trial with levetiracetam as the newer agent by Brodie and colleage in 2007 provided a relative risk of 0.94 with 95 percent confidence interval of 0.80 to 1.10. The combined effect of all newer AEDs showed a relative risk of 0.90 with 95 percent confidence interval of 0.79 to 1.02. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.90 with 95 percent confidence interval of 0.79 to 1.02, and trials having patients 65 years or older showed a relative risk of 0.82 with 95 percent confidence interval of 0.64 to 1.03.

Figure J-29 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of seizure freedom in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. A single trial with lamotrigine as the newer agent by Steiner and colleage in 1999 provided a relative risk of 0.95 with 95 percent confidence interval of 0.56 to 1.63. In the trials with oxcarbazepine as the newer agent, the first trial by Bill and colleague in 1997 provided a relative risk of 0.95 with 95 percent confidence interval of 0.79 to 1.14. The second trial by Guerreiro and colleague in 1997 provided a relative risk of 1.01 with 95 percent confidence interval of 0.78 to 1.31. The combinded effect of the oxcarbazepine trials showed a relative risk of 0.97 with 95 percent confidence interval of 0.84 to 1.12. A single trial with topiramate as the newer agent by Ramsay and colleague in 2007 provided a relative risk of 0.89 with 95 percent confidence interval of 0.80 to 0.98. The combined effect of all newer AEDs showed a relative risk of 0.92 with 95 percent confidence interval of 0.85 to 1.00. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.01 with 95 percent confidence interval of 0.86 to 1.19, trials having patients with generalized epilepsy showed a relative risk of 0.98 with 95 percent confidence interval of 0.85 to 1.14, trials having patients with new onset epilepsy showed a relative risk of 0.97 with 95 percent confidence interval of 0.84 to 1.12, and trials having children 18 years or younger showed a relative risk of 1.01 with 95 percent confidence interval of 0.79 to 1.31.

Figure J-30 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of seizure freedom in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. In the trials with lamtorigine as the newer agent, the first trial by Kwan and colleague in 2009 provided a relative risk of 1.56 with 95 percent confidence interval of 0.88 to 2.78. The second trial by Morrell and colleague in 2008 provided a relative risk of 0.80 with 95 percent confidence interval of 0.63 to 1.01. The third trial by Stephen and colleague in 2007 provided a relative risk of 1.01 with 95 percent confidence interval of 0.77 to 1.34. The fourth trial by Steinhoff and colleague in 2005 provided a relative risk of 0.73 with a 95 percent confidence interval of 0.51 to 0.99. The fifth trial by Fakhoury and colleague in 2004 provided a relative risk of 3.29 with 95 percent confidence interval of 0.99 to 12.40. The sixth trial by Biton and colleague in 2003 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.32 to 1.62. The seventh trial by Biton and colleague in 2001 provided a relative risk of 1.10 with 95 percent confidence interval of 0.64 to 1.90. The combined effect of the lamotrigine trials showed a relative risk of 0.95 with 95 percent confidence interval of 0.76 to 1.19. In the trials with oxcarbazepine as the newer agent, the first trial by Donati and colleague in 2007 provided a relative risk of 1.05 with 95 percent confidence interval of 0.73 to 1.63. The second trial by Christie and colleage in 1997 provided a relative risk of 1.00 with 95 percent confidence interval of 0.76 to 1.30. The combined effect of the oxcarbazepine trials showed a relative risk of 1.01 with 95 percent confidence interval of 0.81 to 1.26. In the trials with topiramate as the newer agent, the first trial by Levisohn and colleague in 2007 provided a relative risk of 0.95 with 95 percent confidence interval of 0.42 to 2.49. The second and third trials by Wheless and colleague in 2004 provided a relative risk of 1.20 and 1.12 with 95 percent confidence interval of 0.72 to 2.60 and 0.66 to 2.44. The fourth and fifth trials by Privitera and colleague in 2003 provided a relative risk of 1.13 and 1.10 with 95 percent confidence interval of 0.80 to 1.71 and 0.72 to 1.55. The combined effect of the topiramate trials showed a relative risk of 1.08 with 95 percent confidence interval of 0.86 to 1.36. The combined effect of all newer AEDs showed a relative risk of 0.97 with 95 percent confidence interval of 0.87 to 1.08. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.02 with 95 percent confidence interval of 0.86 to 1.22, trials having patients with generlized epilepsy showed a relative risk of 0.89 with 95 percent confidence interval of 0.77 to 1.02, trials having patients with new onset epilepsy showed a relative risk of 0.96 with 95 percent confidence interval of 0.83 to 1.11, trials having patients with chronic epilepsy showed a relative risk of 3.29 with 95 percent confidence interval of 0.99 to 12.40, trials having greater than 90 percent females showed a relative risk of 0.80 with 95 percent confidence interval of 0.63 to 1.01, and trials having children 18 years or younger showed a relative risk of 1.10 with 95 percent confidence interval of 0.81 to 1.48.

Figure J-31 Composite forest plot of meta-analysis of seizure freedom for study duration in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of withdrawal due to lack of efficacy in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational trials. A single trial with lamotrigine as the newer agent by Kwan and colleague in 2001 provided a relative risk of 1.05 with 95 percent confidence interval of 0.82 to 1.34. A single trial with oxcarbazepine as the newer agent by Sabers and colleague in 1995 provided a relative risk of 0.79 with 95 percent confidence interval of 0.34 to 1.67. A single trial with topiramate as the newer agent by Ma and colleague in 2009 provided a relative risk of 0.80 with 95 percent confidence interval of 0.68 to 0.92. The combined effect of all newer AEDs showed a relative risk of 0.89 with 95 percent confidence interval of 0.72 to 1.10. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.90 with 95 percent confidence interval of 0.69 to 1.18 and trials having children 18 years or younger showed a relative risk of 0.80 with 95 percent confidence interval of 0.68 to 0.92.

Figure J-32 Composite forest plot of meta-analysis of maximum concentration (Cmax) in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system; Cmax = maximum concentration

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of maximum concentration (Cmax) in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamazepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a mean difference in maximum concentration of -0.11 and 0.39 with 95 percent confidence interval of -1.51 to 1.29 and -1.31 to 2.09, respectively. The third, fourth and fifth trial by Silpakit and colleague in 1997 provided a mean difference of 0.45, 0.04 and 0.45 with 95 percent confidence interval of -1.99 to 2.89, -2.98 to 3.06 and -1.78 to 2.68. The sixth and seventh trial by Oles and colleague in 1992 provided a mean difference of 0.20 and 0.20 with 95 percent confidence interval of -1.14 to 1.54 and -1.08 to 1.48, respectively. The eighth trial by Reunanen and colleague in 1992 provided a mean difference of 0.80 with 95 percent confidence interval of -0.10 and 1.70. The ninth trial by Hartley and colleague in 1991 provided a mean difference of -0.29 with 95 percent confidence interval of -1.94 to 1.37. The tenth trial by Hartley and colleague in 1990 provided a mean difference of 0.04 with 95 percent confidence interval of -1.13 to 1.21. The combined effect of the carbamazepine trials showed a mean difference of 0.28 with 95 percent confidence interval of -0.17 to 0.72. A single lamotrigine trial by Nielsen and colleague in 2008 provided a mean difference of -0.11 wiht 95 percent confidence interval of -8.82 to 8.60. In the phenytoin trials, all 5 trials by Soryal and colleague in 1992 provided a mean difference of -1.30, -0.80, 1.80, -1.30 and -3.30 with 95 percent confidence interval of -8.39 to 5.79, -7.89 to 6.29, -7.69 to 11.29, -8.28 to 5.68, and -8.96 to 2.36, respectively. The combined effect of phenytoin trials showed a mean difference of -1.08 with 95 percent confidence interval of -4.35 to 2.19. The combined effect of carbamazepine, lamotrigine and phenytoin controlled trials showed a mean difference of 0.10 with 95 percent confidence interval of -0.13 to 0.32. In the subgroup analysis, controlled trials with BCS Class I agents showed a mean difference of -0.11 with 95 percent confidence interval of -8.82 to 8.60, trials with BCS Class II agents showed a mean difference of 0.10 with 95 percent confidence interval of -0.13 to 0.33 and trials with only A-rated antiepileptics showed a mean difference of 0.20 with 95 percent confidence interval of -0.73 to 1.13.

Figure J-33 Composite forest plot of meta-analysis of minimum concentration (Cmin) in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system; Cmin = minimum concentration

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of minimum concentration (Cmin) in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamazepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a mean difference in minimum concentration of 0.22 and 0.41 with 95 percent confidence interval of -1.09 to 1.53 and -0.82 to 1.64, respectively. The third, fourth and fifth trial by Silpakit and colleague in 1997 provided a mean difference of 0.07, 0.16 and -0.73 with 95 percent confidence interval of -2.62 to 2.76, -1.91 to 2.23 and -3.14 to 1.68. The sixth trial by Reunanen and colleague in 1992 provided a mean difference of 0.40 with 95 percent confidence interval of -0.31 and 1.11. The seventh trial by Hartley and colleague in 1990 provided a mean difference of 0.08 with 95 percent confidence interval of -0.81 to 0.97. The eighth and ninth trial by Kauko and colleague in 1974 provided a mean difference of -0.61 and -0.54 with 95 percent confidence interval of -2.30 to 1.08 and -2.26 to 1.18, respectively. The combined effect of the carbamazepine trials showed a mean difference of 0.15 with 95 percent confidence interval of -0.25 to 0.56. A single lamotrigine trial by Nielsen and colleague in 2008 provided a mean difference of 0.89 wiht 95 percent confidence interval of -6.07 to 7.85. The combined effect of carbamazepine and lamotrigine controlled trials showed a mean difference of 0.05 with 95 percent confidence interval of -0.21 to 0.31. In the subgroup analysis, controlled trials with BCS Class I agents showed a mean difference of 0.89 wiht 95 percent confidence interval of -6.07 to 7.85, and trials with BCS Class II agents showed a mean difference of 0.15 with 95 percent confidence interval of -0.25 to 0.56.

Figure J-34 Composite forest plot of meta-analysis of steady-state concentration (Css) in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs=antiepileptic drugs; BCS=biopharmaceutics classification system; Css=concentration at steady-state

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of steady-state concentration (Css) in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamazepine controlled trials, the first trial by Reunanen and colleague in 1992 provided a mean difference in steady-state concentration of 0.60 with 95 percent confidence interval of -0.21 and 1.41. The second trials by Hartley and colleague in 1991 provided a mean difference of -0.08 with 95 percent confidence interval of -1.54 to 1.38. The third trials by Jumao-as and colleague in 1989 provided a mean difference of -0.50 with 95 percent confidence interval of -3.84 to 2.84. The fourth trials by Glende and colleague in 1983 provided a mean difference of -0.10 with 95 percent confidence interval of -2.02 to 1.82. The combined effect of the carbamazepine trials showed a mean difference of 0.34 with 95 percent confidence interval of -0.31 to 0.99. In the phenytoin trials, the first trial by Mikati and colleague in 1992 provided a mean difference of 2.30 with 95 percent confidence interval of -3.62 to 8.22. The second, third and fourth trial by Kishore and colleague in 1986 provided a mean difference of 3.82, 2.85 and 3.32 with 95 percent confidence interval of -3.21 to 10.85, -3.23 to 8.93 and -2.84 to 9.48, respectively. The fifth, sixth, seventh and eighth trial by Chen and colleague in 1982 provided a mean difference of 2.30, -4.40, -2.50, and 0.50 with 95 percent confidence interval of -19.50 to 24.10, -23.87 to 15.07, -20.75 to 15.75, and 21.72 to 22.72, respectively. The combined effect of the phenytoin trials showed a mean difference of 2.96 with 95 percent confidence interval of 0.65 to 5.28. The combined effect of the carbamazepine and phenytoin controlled trials showed a mean difference of 0.18 with 95 percent confidence interval of -0.09 to 0.45. In the subgroup analysis, trials with BCS Class II agents showed a mean difference of 0.18 with 95 percent confidence interval of -0.09 to 0.45.

Figure J-35 Composite forest plot of meta-analysis of time to maximum concentration (Tmax) in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system; Tmax = time to maximum concentration.

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of time to maximum concentration (Tmax) in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamazepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a mean difference in time to maximum concentration of 1.00 and 0.42 with 95 percent confidence interval of 0.43 to 1.57 and -0.05 to 0.89, respectively. The third, fourth and fifth trial by Silpakit and colleague in 1997 provided a mean difference of -0.50, -0.23 and 0.11 with 95 percent confidence interval of -1.62 to 0.62, -1.40 to 0.94 and -1.11 to 1.33. The sixth and seventh trial by Oles and colleague in 1992 provided a mean difference of -0.30 and -0.20 with 95 percent confidence interval of -1.15 to 0.55 and -1.06 to 0.66, respectively. The eighth trial by Reunanen and colleague in 1992 provided a mean difference of -0.50 with 95 percent confidence interval of -1.98 to 0.98. The ninth trial by Hartley and colleague in 1991 provided a mean difference of -0.50 with 95 percent confidence interval of -0.99 to -0.01. The combined effect of the carbamazepine trials showed a mean difference of 0.00 with 95 percent confidence interval of -0.43 to 0.43. The combined effect of overall AEDs showed a mean difference of 0.00 with 95 percent confidence interval of -0.43 to 0.43. In the subgroup analysis, trials with BCS Class II agents showed a mean difference of 0.00 with 95 percent confidence interval of -0.43 to 0.43 and trials with only A-rated antiepileptics showed a mean difference of -0.25 with 95 percent confidence interval of -0.85 to 0.35.

Figure J-36 Composite forest plot of meta-analysis of area under the curve (AUC) in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs=antiepileptic drugs; BCS=biopharmaceutics classification system; AUC=area under the curve

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of area under the curve (AUC) in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamazepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a mean difference area under the cureve of -0.46 and 4.92 with 95 percent confidence interval of -16.27 to 15.35 and -13.35 to 23.19, respectively. The third, fourth and fifth trial by Silpakit and colleague in 1997 provided a mean difference of -0.61, 7.39 and 12.62 with 95 percent confidence interval of -39.02 to 37.80, -33.91 to 48.69, and -94.40 to 119.64, respectively. The sixth and seventh trial by Oles and colleague in 1992 provided a mean difference of 0.30 and 2.50 with 95 percent confidence interval of -6.98 to 7.58 and -4.50 to 9.50, respectively. The eighth trial by Reunanen and colleague in 1992 provided a mean difference of 7.00 with 95 percent confidence interval of -2.61 to 16.61. The ninth trial by Hartley and colleague in 1991 provided a mean difference of -1.50 with 95 percent confidence interval of -18.79 to 15.79. The tenth trial by Glende and colleague in 1983 provided a mean difference of -1.30 with 95 percent confidence interval of -44.02 to 41.42. The combined effect of the carbamazepine trials showed a mean difference of 2.34 with 95 percent confidence interval of -1.59 to 6.28. A single lamotrigine trial by Nielsen and colleague in 2008 provided a mean difference of -10.50 wiht 95 percent confidence interval of 86.08 to 65.08. In the phenytoin trials, all 5 trials by Soryal and colleague in 1992 provided a mean difference of -18.70, -13.90, 12.90, -26.40, and -41.80 with 95 percent confidence interval of -90.55 to 53.15, -83.63 to 55.83, -90.09 to 115.89, -104.22 to 51.42, and -101.32 to 17.72, respectively. The combined effect of phenytoin trials showed a mean difference of -18.78 with 95 percent confidence interval of -52.60 to 15.06. The combined effect of carbamazepine, lamotrigine and phenytoin controlled trials showed a mean difference of 0.05 with 95 percent confidence interval of -0.18 to 0.28. In the subgroup analysis, trials with BCS Class I agents showed a mean difference of -10.50 with 95 percent confidence interval of -86.08 to 65.08, trials with BCS Class II agents showed a mean difference of 0.06 with 95 percent confidence interval of -0.17 to 0.30 and trials with only A-rated antiepileptics showed a mean difference of 1.44 with 95 percent confidence interval of -3.60 to 6.49.

Figure J-37 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs; FE = focalized epilepsy

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 0.56 with 95 percent confidence interval of 0.42 to 0.75. The second trial by Rowan and colleague in 2005 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.50 to 0.98. The third, fourth and fifth trial by Chadwick and colleague in 1998 provided a relative risk of 0.03, 0.17 and 0.56 with 95 percent confidence interval of 0.003 to 0.26, 0.05 to 0.59 and 0.24 to 1.38. The combined effect of the gabapentin trials showed a relative risk of 0.51 with 95 percent confidence interval of 0.33 to 0.79. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 0.59 with 95 percent confidence interval of 0.44 to 0.78. The second trial by Rowan and colleague in 2005 provided a relative risk of 0.39 with 95 percent confidence interval of 0.25 to 0.59. The third trial by Steinhoff and colleague in 2005 provided a relative risk of 0.41 with 95 percent confidence interval of 0.18 to 0.91. The fourth trial by Fakhoury and colleague in 2004 provided a relative risk of 0.55 with 95 percent confidence interval of 0.28 to 1.09. The fifth trial by Nieto-Barrera and colleague in 2001 provided a relative risk of 0.61 with 95 percent confidence interval of 0.39 to 0.94. The sixth and seventh trial by Reunanen and colleague in 1996 provided a relative risk of 0.42 and 0.44 with a 95 percent confidence interval of 0.14 to 1.27 and 0.15 to 1.31, respectively. The eighth trial by Brodie and colleague in 1999 provided a relative risk of 0.42 with a 95 percent confidence interval of 0.25 to 0.73. The ninth trial by Brodie and colleague in 1995 provided a relative risk of 0.55 with 95 percent confidence interval of 0.31 to 1.00. The combined effect of the lamotrigine trials showed a relative risk of 0.52 with 95 percent confidence interval of 0.43 to 0.61. In the trials with oxcarbazepine as the newer agent, the first trial by Marson and colleague in 2007 provided a relative risk of 0.87 with 95 percent confidence interval of 0.64 to 1.16. The second trial by Dam and colleague in 1989 provided a relative risk of 0.55 with 95 percent confidence interval of 0.30 to 1.00. The third trial by Danner and colleague in 1988 provided a relative risk of 0.36 with 95 percent confidence interval of 0.06 to 2.18. The combined effect of the oxcarbazepine trials showed a relative risk of 0.76 with 95 percent confidence interval of 0.56 to 1.04. In the trials with topiramate as the newer agent, the first trial by Kang and colleague in 2007 provided a relative risk of 1.12 with 95 percent confidence interval of 0.38 to 3.29. The second trial by Marson and colleague in 2007 provided a relative risk of 1.08 with 95 percent confidence interval of 0.85 to 1.36. The third and fourth trials by Privitera and colleague in 2003 provided a relative risk of 0.75 and 1.09 with 95 percent confidence interval of 0.46 to 1.26 and 0.69 to 1.78. The fifth and sixth trials by Wheless and colleague in 2004 provided a relative risk of 2.42 and 4.13 with 95 percent confidence interval of 0.27 to 25.18 and 0.50 to 41.25. The combinded effect of the topiramate trials showed a relative risk of 1.04 with 95 percent confidence interval of 0.86 to 1.26. In the trials with vigabatrin as the newer agent, the first trial by Sobaniec and colleague in 2005 provided a relative risk of 1.08 with 95 percent confidence interval of 0.32 to 3.60. The second trial by Chadwick and colleague in 1999 provided a relative risk of 0.71 with 95 percent confidence interval of 0.50 to 1.00. The third trial by Tanganelli and colleague in 1996 provided a relative risk of 0.32 with 95 percent confidence interval of 0.03 to 3.74. The fourth trial by Kalviainen and colleague in 1995 provided a relative risk of 0.04 with 95 percent confidence interval of 0.004 to 0.37. The combined effect of all vigabatrin trials showed a relative risk of 0.58 with 95 percent confidence interval of 0.23 to 1.45. The combined effect of all newer AEDs showed a relative risk of 0.63 with 95 percent confidence interval of 0.53 to 0.73. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.73 with 95 percent confidence interval of 0.58 to 0.91, trials having patients with new onset epilepsy showed a relative risk of 0.50 with 95 percent confidence interval of 0.37 to 0.66, trials having greater than 90 percent males showed a relative risk of 0.53 with 95 percent confidence interval of 0.30 to 0.94, trials having patients with chronic epilepsy showed a relative risk of 0.55 with 95 percent confidence interval of 0.28 to 1.09, trials having children 18 years or younger showed a relative risk of 1.08 with 95 percent confidence interval of 0.52 to 2.23, trials having patients between the ages of 18-65 years showed a relative risk of 0.32 with 95 percent confidence interval of 0.03 to 3.74 and trials having patients 65 years or older showed a relative risk of 0.42 with 95 percent confidence interval of 0.27 to 0.66.

Figure J-38 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational studies. In the trials with lamtorigine as the newer agent, the first study by Kim and colleages in 2007 provided relative risk of 1.24 with 95 percent confidence interval of 0.07 to 20.32. The second study by Kwan and colleague in 2001 provided relative risk of 0.38 with 95 percent confidence interval of 0.19 to 0.73. The combined effect of both studies showed a relative risk of 0.40 with 95 percent confidence interval of 0.20 to 0.78. A single study with levetiracetam as the newer agent by Perry and colleages in 2008 provided a relative risk of 2.42 with 95 percent confidence interval of 0.45 to 14.69. A single study with oxcarbazepine as the newer agent by Clemens and colleagues in 2004 provided a relative risk of 3.00 with 95 percent confidence interval of 0.26 to 35.71. A single study with topiramate as the newer agent by Kim and colleagues in 2009 provided a relative risk of 0.37 with 95 percent confidence interval of 0.06 to 2.14. A single study with vigabatrin as the newer agent by Gobbi and colleagues in 1999 provided a relative risk of 1.08 with 95 percent confidence interval of 0.06 to 18.47. The combined effect of all newer AEDs showed a relative risk of 0.51 with 95 percent confidence interval of 0.28 to 0.92. In the subgroup analysis, studies having patients with partial epilepsy showed a relative risk of 2.58 with 95 percent confidence interval of 0.47 to 14.09, studies having patients with new onset epilepsy showed a relative risk of 0.56 with 95 percent confidence interval of 0.24 to 1.30, studies having patients with chronic epilepsy showed a relative risk of 3.00 with 95 percent confidence interval of 0.26 to 35.71, studies having children less than 18 years of age showed a relative risk of 0.98 with 95 percent confidence interval of 0.25 to 3.77.

Figure J-39 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with controlled or sustained release carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of mortality in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleagues in 2007 provided a relative risk of 1.06 with 95 percent confidence interval of 0.57 to 1.97. The second trial by Rowan and colleagues in 2005 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.36 to 1.55. The combined effect of the two trials showed a relative risk of 0.92 with 95 percent confidence interval of 0.57 to 1.48. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 0.67 with 96 percent confidence interval of 0.33 to 1.34. The second trial by Rowan and colleague in 2005 provided relative risk of 0.53 with 95 percent confidence interval of 0.23 to 1.19. The third trial by Fakhoury and colleagues in 2004 provided a relative risk of 2.36 with a 95 percent confidence interval of 0.22 to 26.14. The fourth trial by Brodie and colleaguesin 1999 provided a relative risk of 0.01 with a 95 percent confidence interval of 0.009 to 1.04. The fifth and sixth trial by Reunanen and colleagues in 1996 provided a relative risk of 1.53 and 1.59 with a 95 percent confidence interval of 0.3 to 18.56 and 0.13 to 19.22, respectively. The combined effect of the six trials showed a relative risk of 0.63 with 95 percent confidence interval of 0.37 to 1.04. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.50 with 95 percent confidence interval of 0.19 to 1.27. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.94 with 95 percent confidence interval of 0.50 to 1.78. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 2.01 with 95 percent confidence interval of 0.26 to 15.27. The combined effect of all newer AEDs showed a relative risk of 0.75 with 95 percent confidence interval of 0.51 to 1.12. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.63 with 95 percent confidence interval of 0.34 to 1.18, trials having patients with chronic epilepsy showed a relative risk of 2.36 with 95 percent confidence interval of 0.22 to 26.14, trials having greater than 90 percent males showed a relative risk of 0.64 with 95 percent confidence interval of 0.33 to 1.23, and trials having patients 65 years or older showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 1.04.

Figure J-40 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in controlled clinical trials. In the trial with lamotrigine as the newer agent, by Steiner and colleagues in 1999 provided a relative risk of 0.80 with a 95 percent confidence interval of 0.42 to 1.51. In the trials with oxcarbazepine as the newer agent, the first trial by Bill and colleages in 1997 provided relative risk of 0.31 with a 95 percent confidence interval of 0.12 to 0.80. The second trial by Guerreiro and colleague in 1997 provided relative risk of 0.14 with a 95 percent confidence interval of 0.04 to 0.54. The combined effect of the two trials showed a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.55. The combined effect of all newer AEDs showed a relative risk of 0.38 with 95 percent confidence interval of 0.14 to 1.03. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.38 with a 95 percent confidence interval of 0.14 to 1.03, trials having patients 18 years of age or younger showed a relative risk of 0.14 with a 95 percent confidence interval of 0.04 to 0.54.

Figure J-41 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs; GE = generalized epilepsy

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with lamotrigine as the newer agent, the first trial by Glauser and colleagues in 2010 provided a relative risk of 0.71 with 95 percent confidence interval of 0.45 to 1.12. The second trial by Kwan and colleagues in 2009 provided a relative risk of 1.19 with a 95 percent confidence interval of 0.39 to 3.58. The third trial by Morrell and colleagues in 2008 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.42 to 2.44. The fourth trial by Marson and colleagues in 2007 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.44 to 1.15. The fifth trial by Stephen and colleagues in 2007 provided a relative risk of 0.56 with a 95 percent confidence interval of 0.32 to 0.99. The fifth trial by Stephen and colleagues in 2007 provided a relative risk of 0.56 with a 95 percent confidence interval of 0.32 to 0.99. The fifth trial by Stephen and colleagues in 2007 provided a relative risk of 0.56 with a 95 percent confidence interval of 0.32 to 0.99. The sixth trial by Steinhoff and colleagues in 2005 provided a relative risk of 1.82 with a 95 percent confidence interval of 0.25 to 13.53. The seventh trial by Coppola and colleagues in 2004 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.06 to16.92. The eighth trial by Fakhoury and colleagues in 2004 provided a relative risk of 0.64 with a 95 percent confidence interval of 0.32 to1.32. The combined effect of the two trials showed a relative risk of 0.92 with 95 percent confidence interval of 0.57 to 1.48. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 0.67 with 96 percent confidence interval of 0.33 to 1.34. The second trial by Rowan and colleague in 2005 provided relative risk of 0.53 with 95 percent confidence interval of 0.23 to 1.19. The third trial by Fakhoury and colleagues in 2004 provided a relative risk of 2.36 with a 95 percent confidence interval of 0.22 to 26.14. The fourth trial by Brodie and colleaguesin 1999 provided a relative risk of 0.01 with a 95 percent confidence interval of 0.009 to 1.04. The fifth and sixth trial by Reunanen and colleagues in 1996 provided a relative risk of 1.53 and 1.59 with a 95 percent confidence interval of 0.3 to 18.56 and 0.13 to 19.22, respectively. The combined effect of the six trials showed a relative risk of 0.63 with 95 percent confidence interval of 0.37 to 1.04. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.50 with 95 percent confidence interval of 0.19 to 1.27. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.94 with 95 percent confidence interval of 0.50 to 1.78. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 2.01 with 95 percent confidence interval of 0.26 to 15.27. The combined effect of all newer AEDs showed a relative risk of 0.75 with 95 percent confidence interval of 0.51 to 1.12. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.63 with 95 percent confidence interval of 0.34 to 1.18, trials having patients with chronic epilepsy showed a relative risk of 2.36 with 95 percent confidence interval of 0.22 to 26.14, trials having greater than 90 percent males showed a relative risk of 0.64 with 95 percent confidence interval of 0.33 to 1.23, and trials having patients 65 years or older showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 1.04.

Figure J-42 Composite forest plot of meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational studies. In the studies with lamotrigine as the newer agent, the first study by Kim and colleages in 2007 provided relative risk of 1.82 with 95 percent confidence interval of 0.11 to 30.02. The second study by Kwan and colleague in 2001 provided relative risk of 0.80 with 95 percent confidence interval of 0.35 to 1.78. The combined effect of both studies showed a relative risk of 0.83 with 95 percent confidence interval of 0.37 to 1.86. The combined effect of all newer AEDs showed a relative risk of 0.83 with 95 percent confidence interval of 0.37 to 1.86. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.83 with 95 percent confidence interval of 0.37 to 1.86.

Figure J-43 Composite forest plot of meta-analysis of withdrawals due to adverse events in patients with epilepsy taking generic antiepileptic drugs compared with the corresponding innovator antiepileptic drug

AEDs = antiepileptic drugs; BCS = biopharmaceutics classification system

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of withdrawal due to adverse events in patients with epilepsy taking generic antiepileptic drugs compared to the corresponding innovator antiepileptic drug. In the carbamzepine controlled trials, the first and second trial by Aldenkamp and colleague in 1998 provided a relative risk 1.00 and 1.00 with 95 percent confidence interval of 0.04 to 24.53 and 0.04 to 24.53, respectively. The third and fourth trial by Oles and colleague in 1992 provided relative risk of 0.33 and 3.00 with 95 percent confidence interval of 0.03 to 3.84 and 0.26 to 35.71, respectively. The fifth trial by Reunanen and colleague in 1992 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.94. The sixth trial by Hartley and colleague in 1991 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.71. The seventh trial by Hartley and colleague in 1990 provided a relative risk of 0.33 with 95 percent confidence interval of 0.03 to 3.87. The eighth trial by Jumao-as and colleague in 1989 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.60. The ninth trial by Glende and colleague in 1983 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.00. The combined effect of the carbamazepine trials showed a relative risk of 0.85 with 95 percent confidence interval of 0.25 to 2.88. In the phenytoin trials, the first trial by Mikati and colleague in 1992 provided a relative risk of 0.33 with 95 percent confidence interval of 0.03 to 3.66. The second, third and fourth trial by Kishore and colleague in 1986 provided a relative risk of 1.00 with 95 percent confidence interval of 0.03 to 32.24. The fifth trial by Lund and colleague in 1974 provided a relative risk of 1.00 with 95 percent confidence interval of 0.06 to 16.53. The combined effect of phenytoin trials showed a relative risk of 0.66 with 95 percent confidence interval of 0.10 to 4.42. The combined effect of carbamazepine and phenytoin controlled trials showed a relative risk of 0.79 with 95 percent confidence interval of 0.28 to 2.20. In the subgroup analysis, controlled trials with BCS Class II agents showed a relative risk of 0.79 with 95 percent confidence interval of 0.28 to 2.20 and trials with only A-rated antiepileptics showed a relative risk of 1.00 with 95 percent confidence interval of 0.11 to 9.22.

Figure J-44 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters following author name and study year represent study arms within the same trial.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. In the trials with gabapentin as the newer agent, the first study by Marson and colleages in 2007 provided relative risk of 0.95 with 95 percent confidence interval of 0.53 to 1.72. The second trial by Rowan and colleagues in 2005 provided relative risk of 0.87 with 95 percent confidence interval of 0.54 to 1.39. The third trial by Chadwick and colleagues in 1998 provided relative risk of 1.03 with 95 percent confidence interval of 0.36 to 3.17. The fourth trial by Chadwick and colleagues in 1998 provided relative risk of 1.00 with 95 percent confidence interval of 0.35 to 3.09. The combined effect of all newer AEDs showed a relative risk of 0.93 with 95 percent confidence interval of 0.67 to 1.28. In the trials with lamotrigine as the newer agent, the first trial by Marson and colleages in 2007 provided relative risk of 1.00 with 95 percent confidence interval of 0.56 to 1.79.The second trial by Rowan and colleagues in 2005 provided relative risk of 1.09 with 95 percent confidence interval of 0.70 to 1.69. The third trial by Fakhoury and colleagues in 2004 provided relative risk of 0.59 with 95 percent confidence interval of 0.18 to 1.96. The fourth trial by Nieto-Barrera and colleagues in 2001 provided relative risk of 0.84 with 95 percent confidence interval of 0.53 to 1.33. The fourth trial by Nieto-Barrera and colleagues in 2001 provided relative risk of 0.84 with 95 percent confidence interval of 0.53 to 1.33. The fifth trial by Brodie and colleagues in 1999 provided relative risk of 0.53 with 95 percent confidence interval of 0.23 to 1.27. The sixth trial by Reunanen and colleagues in 1996 provided relative risk of 1.94 with 95 percent confidence interval of 0.84 to 1.33. The seventh trial by Reunanen and colleagues in 1996 provided relative risk of 1.92 with 95 percent confidence interval of 0.83 to 4.61. The eighth trial by Brodie and colleagues in 1995 provided relative risk of 1.20 with 95 percent confidence interval of 0.81 to 1.79. The combined effect showed a relative risk of 1.06 with 95 percent confidence interval of 0.84 to 1.33. In the trials with oxcarbazepine as the newer agent, the first trial by Donati and colleages in 2007 provided relative risk of 1.53 with 95 percent confidence interval of 0.38 to 6.41. The second trial by Marson and colleagues in 2007 provided relative risk of 0.77 with 95 percent confidence interval of 0.36 to 1.62. The third trial by Reinikainen and colleagues in 1987 provided relative risk of 0.37 with 95 percent confidence interval of 0.03 to 4.26. The combined effect of oxcarbazepine showed a relative risk of 0.85 with 95 percent confidence interval of 0.44 to 1.66. In the trials with topiramate as the newer agent, the first trial by Marson and colleages in 2007 provided relative risk of 0.81 with 95 percent confidence interval of 0.44 to 1.49. The second trial by Privitera and colleagues in 2003 provided relative risk of 0.52 with 95 percent confidence interval of 0.29 to 0.93. The third trial by Privitera and colleagues in 2003 provided relative risk of 0.39 with 95 percent confidence interval of 0.21 to 0.74. The fourth trial by Wheless and colleagues in 2004 provided relative risk of 1.69 with 95 percent confidence interval of 0.63 to 5.57. The fifth trial by Wheless and colleagues in 2004 provided relative risk of 0.71 with 95 percent confidence interval of 0.22 to 2.60. The combined effect of topiramate showed a relative risk of 0.63 with 95 percent confidence interval of 0.41 to 0.96. In the trials with vigabatrin as the newer agent, the first trial by Chadwick and colleages in 1999 provided relative risk of 0.98 with 95 percent confidence interval of 0.69 to 1.40. The second trial by Tanganelli and colleagues in 1996 provided relative risk of 8.66 with 95 percent confidence interval of 0.90 to 88.91. The third trial by Kalviainen and colleagues in 1995 provided relative risk of 1.05 with 95 percent confidence interval of 0.11 to 9.84. The combined effect of vigabatrin showed a relative risk of 1.13 with 95 percent confidence interval of 0.55 to 2.32. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.92 with 95 percent confidence interval of 0.78 to 1.08. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 2.11 with 95 percent confidence interval of 0.54 to 8.19, patients with new onset epilepsy showed a relative risk of 1.03 with 95 percent confidence interval of 0.85 to 1.25, patients with chronic epilepsy showed a relative risk of 0.55 with a 95 percent confidence interval of 0.17 to 1.78, trials with more than 90 percent males showed a relative risk of 0.98 and a 95 percent confidence interval of 0.66 to 1.46, trials having patients 18 years of age or younger showed a relative risk of 0.83 with a 95 percent confidence interval of 0.43 to 1.61, trials having patients between the ages of 18 and 65 showed a relative risk of 8.66 with a 95 percent confidence interval of 0.90 to 88.91, trials having patients 65 years of age and above showed a relative risk of 0.59 with a 95 percent confidence interval of 0.25 to 1.39.

Figure J-45 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational studies. In the studies with lamotrigine as the newer agent, the first study by Kwan and colleages in 2001 provided relative risk of 0.45 with 95 percent confidence interval of 0.11 to 1.74. The second study by Ma and colleague in 2009 provided relative risk of 0.42 with 95 percent confidence interval of 0.12 to 1.50. The combined effect of all newer AEDs showed a relative risk of 0.43 with 95 percent confidence interval of 0.16 to 1.18. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.43 with 95 percent confidence interval of 0.16 to 1.18, studies having patients 18 years of age or younger showed a relative risk of 0.42 with a 95 percent confidence interval of 0.12 to 1.50.

Figure J-46 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with controlled or sustained release carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to controlled or sustained release of carbamazepine in clinical trials. In the studies with lamotrigine as the newer agent, the study by Saetre and colleages in 2007 provided relative risk of 0.99 with 95 percent confidence interval of 0.44 to 2.22. In the studies with levetiracetam as the newer agent, the study by Brodie and colleages in 2007 provided relative risk of 0.81 with 95 percent confidence interval of 0.60 to 1.10. The combined effect of all newer AEDs showed a relative risk of 0.83 with 95 percent confidence interval of 0.63 to 1.10. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.83 with 95 percent confidence interval of 0.63 to 1.10, studies having patients 65 years of age or greater showed a relative risk of 0.99 with a 95 percent confidence interval of 0.44 to 2.22.

Figure J-47 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the studies with lamotrigine as the newer agent, the study by Steiner and colleages in 1999 provided relative risk of 0.55 with 95 percent confidence interval of 0.26 to 1.14. In the studies with Oxcarbazepine as the newer agent, the study by Bill and colleages in 1997 provided relative risk of 0.77 with 95 percent confidence interval of 0.46 to 1.30. The second study by Guerreiro and colleagues in 1997 provided relative risk of 0.91 with 95 percent confidence interval of 0.46 to 1.81. In the trials with topiramate as the newer agent, studies by Ramsay and colleagues in 2007 provided relative risk of 0.71 with 95 percent confidence interval of 0.34 to 1.45. The combined effect of all newer AEDs showed a relative risk of 0.74 with 95 percent confidence interval of 0.53 to 1.02. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.75 with 95 percent confidence interval of 0.52 to 1.08, studies having patients 18 years of age or younger showed a relative risk of 0.91 with a 95 percent confidence interval of 0.46 to 1.81.

Figure J-48 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 0.34 with 95 percent confidence interval of 0.11 to 1.07. In the trials with lamotrigine as the newer agent, the first trial by Glauser and colleages in 2010 provided relative risk of 0.99 with 95 percent confidence interval of 0.47 to 2.09.The second trial by Kwan and colleagues in 2009 provided relative risk of 0.29 with 95 percent confidence interval of 0.04 to 1.83. The third trial by Morrell and colleagues in 2008 provided relative risk of 0.75 with 95 percent confidence interval of 0.48 to 1.17. The fourth trial by Marson and colleagues in 2007 provided relative risk of 1.19 with 95 percent confidence interval of 0.39 to 3.64.The fifth trial by Coppola and colleagues in 2004 provided relative risk of 5.00 with 95 percent confidence interval of 0.49 to 54.40. The sixth trial by Fakhoury and colleagues in 2004 provided relative risk of 1.39 with 95 percent confidence interval of 0.50 to 4.01. The seventh trial by Biton and colleagues in 2003 provided relative risk of 1.85 with 95 percent confidence interval of 0.56 to 6.33. The eighth trial by Biton and colleagues in 2001 provided relative risk of 2.35 with 95 percent confidence interval of 0.81 to 6.95. The combined effect showed a relative risk of 1.03 with 95 percent confidence interval of 0.73 to 1.45. In the trials with oxcarbazepine as the newer agent, the first trial by Donati and colleages in 2007 provided relative risk of 0.45 with 95 percent confidence interval of 0.17 to 1.19. The second trial by Christie and colleagues in 1997 provided relative risk of 0.59 with 95 percent confidence interval of 0.31 to 1.10. The combined effect of oxcarbazepine showed a relative risk of 0.54 with 95 percent confidence interval of 0.32 to 0.93. In the trials with topiramate as the newer agent, the first trial by Levisohn and colleages in 2007 provided relative risk of 2.37 with 95 percent confidence interval of 0.46 to 14.55. The second trial by Marson and colleagues in 2007 provided relative risk of 1.39 with 95 percent confidence interval of 0.47 to 4.11. The third trial by Privitera and colleagues in 2003 provided relative risk of 0.83 with 95 percent confidence interval of 0.42 to 1.69. The fourth trial by Privitera and colleagues in 2003 provided relative risk of 0.63 with 95 percent confidence interval of 0.31 to 1.33. The fifth trial by Wheless and colleagues in 2004 provided relative risk of 2.33 with 95 percent confidence interval of 0.69 to 10.28. The sixth trial by Wheless and colleagues in 2004 provided relative risk of 0.97 with 95 percent confidence interval of 0.24 to 4.66. The combined effect of topiramate showed a relative risk of 0.94 with 95 percent confidence interval of 0.62 to 1.43. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.90 with 95 percent confidence interval of 0.70 to 1.16. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.64 with 95 percent confidence interval of 0.21 to 1.98, patients with generalized epilepsy showed a relative risk of 1.20 with 95 percent confidence interval of 0.60 to 2.41, patients with new onset epilepsy showed a relative risk of 0.80 with a 95 percent confidence interval of 0.50 to 1.27, patients with chronic epilepsy showed a relative risk of 1.01 with a 95 percent confidence interval of 0.39 to 2.65, trials with more than 90 percent females showed a relative risk of 0.75 and a 95 percent confidence interval of 0.48 to 1.17, trials having patients 18 years of age or younger showed a relative risk of 0.95 with a 95 percent confidence interval of 0.52 to 1.75.

Figure J-49 Composite forest plot of meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of headache in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational studies. In the studies with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 1.36 with 95 percent confidence interval of 0.29 to 6.19. In the studies with topiramate as the newer agent, the study by Ma and colleages in 2009 provided relative risk of 0.55 with 95 percent confidence interval of 0.16 to 1.82. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.77 with 95 percent confidence interval of 0.28 to 2.13. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.77 with 95 percent confidence interval of 0.28 to 2.13, studies having patients 18 years of age or younger showed a relative risk of 0.55 with a 95 percent confidence interval of 0.16 to 1.82.

Figure J-50 Composite forest plot of meta-analysis of fatigue in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of fatigue in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in controlled clinical trials. In the trials with gabapentin as the newer agent, the first, second and third trial by Chadwick and colleague in 1998 provided a relative risk of 0.42, 0.42 and 0.27 with 95 percent confidence interval of 0.18 to 0.299, 0.18 to 0.99 and 0.11 to 0.71. The combined effect of the gabapentin trials showed a relative risk of 0.37 with 95 percent confidence interval of 0.22 to 0.62. A single trial with lamotrigine as the newer agent by Steinhoff and colleague in 2005 provided a relative risk of 0.34 with 95 percent confidence interval of 0.20 to 0.58. A single trial with oxcarbazepine as the newer agent by Donati and colleague in 2007 provided a relative risk of 0.89 with 95 percent confidence interval of 0.31 to 2.70. In the trials with topiramate as the newer agent, the first and second trial by Wheless and colleague in 2004 provided a relative risk of 0.91 and 1.47 with 95 percent confidence interval of 0.25 to 3.72 and 0.46 to 5.66. The third and fourth trial by Privitera and colleague in 2003 provided a relative risk of 0.41 and 0.50 with 95 percent confidence interval of 0.23 to 0.77 and 0.28 to 0.91. The combinded effect of the topiramate trials showed a relative risk of 0.54 with 95 percent confidence interval of 0.35 to 0.83. In the trials with vigabatrin as the newer agent, the first trial by Chadwick and colleague in 1999 provided a relative risk of 0.90 with 95 percent confidence interval of 0.63 to 1.29. The second trial by Tanganelli and colleague in 1996 provided a relative risk of 1.92 with 95 percent confidence interval of 0.59 to 6.51. The combined effect of all vigabatrin trials showed a relative risk of 1.02 with 95 percent confidence interval of 0.59 to 1.76. The combined effect of all newer AEDs showed a relative risk of 0.57 with 95 percent confidence interval of 0.41 to 0.80. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 0.74 with 95 percent confidence interval of 0.26 to 2.13, trials having patients with new onset epilepsy showed a relative risk of 0.60 with 95 percent confidence interval of 0.33 to 1.07, trials having children 18 years or younger showed a relative risk of 1.03 with 95 percent confidence interval of 0.47 to 2.28, and trials having patients between the ages of 18-65 years showed a relative risk of 1.92 with 95 percent confidence interval of 0.59 to 6.51.

Figure J-51 Composite forest plot of meta-analysis of fatigue in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of fatigue in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in controlled clinical trials. In the trials with felbamate as the newer agent, the first trial by Faught and colleague in 1993 provided a relative risk of 0.21 with 95 percent confidence interval of 0.02 to 2.19. The second trial by Sachdeo and colleague in 1992 provided a relative risk of 1.50 with 95 percent confidence interval of 0.33 to 7.04. In the trial with lamtorigine as the newer agent, the first trial by Glauser and colleague in 2010 provided a relative risk of 0.71 with 95 percent confidence interval of 0.37 to 1.38. The second trial by Steinhoff and colleague in 2005 provided a relative risk of 0.55 with a 95 percent confidence interval of 0.15 to 1.91. The combined effect of the lamotrigine trials showed a relative risk of 0.68 with 95 percent confidence interval of 0.37 to 1.23. A single trial with oxcarbazepine as the newer agent by Donati and colleage in 2007 provided a relative risk of 1.85 with 95 percent confidence interval of 0.48 to 7.58. In the trials with topiramate as the newer agent, the first trial by Levisohn and colleague in 2007 provided a relative risk of 0.32 with 95 percent confidence interval of 0.07 to 1.40. The second and third trial by Wheless and colleague in 2004 provided a relative risk of 0.75 and 1.22 with 95 percent confidence interval of 0.22 to 3.06 and 0.40 to 4.65. The fourth and fifth trials by Privitera and colleague in 2003 provided a relative risk of 0.41 and 0.50 with 95 percent confidence interval of 0.21 to 0.85 and 0.26 to 1.01. The combined effect of the topiramate trials showed a relative risk of 0.51 with 95 percent confidence interval of 0.33 to 0.78. The combined effect of all newer AEDs showed a relative risk of 0.61 with 95 percent confidence interval of 0.44 to 0.85. In the subgroup analysis, trials having patients with partial epilepsy showed a relative risk of 1.30 with 95 percent confidence interval of 0.45 to 3.73, trials having patients with generlized epilepsy showed a relative risk of 0.61 with 95 percent confidence interval of 0.35 to 1.08, trials having patients with new onset epilepsy showed a relative risk of 0.82 with 95 percent confidence interval of 0.50 to 1.33, trials having patients with chronic epilepsy showed a relative risk of 0.82 with 95 percent confidence interval of 0.13 to 5.10, and trials having children 18 years or younger showed a relative risk of 0.87 with 95 percent confidence interval of 0.52 to 1.47.

Figure J-52 Composite forest plot of meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. The trial with gabapentin as the newer agent by Chadwick and colleagues in 1998 provided a relative risk of 0.21 with a 95 confidence interval of 0.04 to 0.96 for patients who received 300 milligrams of gabapenin, a relative risk of 0.51 with a 95 percent confidence interval of 0.15 to 1.80 for patients who received 900 milligrams of gabapentin and a relative risk of 0.50 with a 95 percent confidence interval of 0.15 to 1.75 for patients who received 1800 milligrams of gabapentin. The combinded effect provided a relative risk of 0.41 with a 95 percent confidence interval of 0.18 to 0.93. In the trials with lamotrigine as the newer agent, the trial by Fakhoury and colleagues in 2004 provided a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.02. The second trial by Nieto-Barrera and colleagues in 2001 provided a raltaive risk of 0.39 with a 95 percent confidence interval of 0.21 to 0.71. The third trial by Brodie and colleagues in 1999 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.21 to 0.80. The fourth trial by Reuanenen and colleagues in 1996 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.15 to 0.86 for the patients receiving 100 milligrams of lamotrigine and a relative risk of 0.37 with a 95 percent confidence interval of 0.15 to 0.90. The fifth trial by Brodie and colleagues in 1995 provided a relative risk of 0.54 with a 95 percent confidence interval of 0.31 to 0.94. The combined effect provided a relative risk of 0.44 with 95 percent confidence interval of 0.33 to 0.58. In the trials with topiramate as the newer agent, the trial by Kang and colleagues in 2007 provided relative risk of 1.30 with 95 percent confidence interval of 0.46to 3.71. The second trial by Wheless and colleagues in 2004 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.23 to 4.97 for patients who received 100 milligrams of topiramate and a relative risk of 0.39 with a 95 percent confidence interval of 0.07 to 2.39. The combined effect of topiramate provided a relative risk of 1.00 with a 95 percent confidence interval of 0.43 to 2.30. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.47 with 95 percent confidence interval of 0.36 to 0.61. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 1.30 with a 95 percent confidence interval of 0.46 to 3.71, patients with new onset epilepsy showed a relative risk of 0.48 with 95 percent confidence interval of 0.33 to 0.69, patients with chronic epilepsy provided a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.02, trials having patients 18 years of age or younger showed a relative risk of 0.68 with 95 percent confidence interval of 0.33 to 1.39, trials having patients 65 years of age or older showed a relative risk of 0.47 with a 95 percent confidence interval of 0.18 to 1.21.

Figure J-53 Composite forest plot of meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational studies. The study with lamotrigine as the newer agent by Kwan and colleages in 2001 provided relative risk of 0.41 with 95 percent confidence interval of 0.04 to 3.97. In the studies with levetiracetam as the newer agent, the study by Perry and colleages in 2008 provided relative risk of 0.23 with 95 percent confidence interval of 0.09 to 0.57. The study with topiramate as the newer agent, the study by Ma and colleages in 2009 provided relative risk of 0.28 with 95 percent confidence interval of 0.02 to 3.38. Thehe study with Vigabatrin as the newer agent by Sobaniec and colleages in 2005 provided relative risk of 0.54 with 95 percent confidence interval of 0.12 to 2.31. The combined effect of all newer AEDs showed a relative risk of 0.30 with 95 percent confidence interval of 0.14 to 0.62. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.28 with 95 percent confidence interval of 0.13 to 0.63, patients with new onset epilepsy showed a relative risk of 0.26 with 95 percent confidence interval of 0.11 to 0.58, studies in patients with chronic epilepsy showed a relative risk of 0.54 with a 95 percent confidence interval of 0.12 to 2.31, studies in patients 18 years of age or younger showed a relative risk of 0.28 with a 95 percent confidence interval of 0.13 to 0.62.

Figure J-54 Composite forest plot of meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trial with lamotrigine as the newer agent, the trial by Steiner and colleages in 1999 provided relative risk of 0.25 with 95 percent confidence interval of 0.11 to 0.54. In the trials with Oxcarbazepine as the newer agent, the study by Bill and colleages in 1997 provided relative risk of 1.04 with 95 percent confidence interval of 0.73 to 1.50. The second trial by Guerreiro and colleagues in 1997 provided relative risk of 0.84 with 95 percent confidence interval of 0.53 to 1.33. The trial with topiramate as the newer agent, by Ramsay and colleagues in 2007 provided a relative risk of 0.86 with 95 percent confidence interval of 0.46 to 1.59. The combined effect of all newer AEDs showed a relative risk of 0.72 with 95 percent confidence interval of 0.44 to 1.18. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.66 with 95 percent confidence interval of 0.34 to 1.30, trials having patients 18 years of age or younger showed a relative risk of 0.84 with a 95 percent confidence interval of 0.53 to 1.33.

Figure J-55 Composite forest plot of meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 0.51 with 95 percent confidence interval of 0.07 to 3.78. In the trials with lamotrigine as the newer agent, the trial by Glauser and colleages in 2010 provided relative risk of 0.74 with 95 percent confidence interval of 0.19 to 2.91. The fourth trial by Fakhoury and colleagues in 2004 provided a relative risk of 0.79 with a 95 percent confidence interval of 0.34 to 1.90. The third trial by Biton and colleagues in 2003 provided relative risk of 0.37 with 95 percent confidence interval of 0.06 to 2.34. The fourth trial by Biton and colleagues in 2001 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.13 to 0.80. The fifth trial by Sachedo and colleagues in 1992 provided a relative risk of 2.00 with a 95 percent confidence interval of 0.36 to 1.45. The combined effect provided a relative risk of 0.48 with 95 percent confidence interval of 0.27 to 0.86. The trial with oxcarbazepine as the newer agent by Christie and colleagues in 1997 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.43 to 1.28. In the trials with topiramate as the newer agent, the trial by Levisohn and colleagues in 2007 provided a relative risk of 2.44 with a 95 percent confidence interval of 0.25 to 26.45. The trial by Wheless and colleagues in 2004 provided at relative risk of 0.42 with a 95 percent confidence interval of 0.14 to 1.44 for the patients who received 100 milligrams of topiramate and a relative risk of 0.16 with a 95 percent confidence interval of 0.04 to 0.75 for the patients who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.38 with a 95 percent confidence interval of 0.12 to 1.21. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.65 with 95 percent confidence interval of 0.43 to 0.98. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 1.55 with a 95 percent confidence interval of 0.54 to 4.43, patients with generalized epilepsy showed a relative risk of 0.94 with a 95 percent confidence interval of 0.25 to 3.53, patients with new onset epilepsy showed a relative risk of 0.58 with 95 percent confidence interval of 0.33 to 1.00, patients with chronic epilepsy showed a relative risk of 1.10 with a 95 percent confidence interval of 0.55 to 2.21, trials having patients 18 years of age or younger showed a relative risk of 0.39 with 95 percent confidence interval of 0.17 to 0.89.

Figure J-56 Composite forest plot of meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of somnolence in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational studies. In the studies with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 1.29 with 95 percent confidence interval of 0.14 to 12.28. In studies with topiramate as the newer agent, studies by Ma and colleagues in 2009 provided relative risk of 0.23 with 95 percent confidence interval of 0.02 to 2.46. The combined effect of all newer AEDs showed a relative risk of 0.58 with 95 percent confidence interval of 0.08 to 4.38. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.58 with 95 percent confidence interval of 0.08 to 4.38, studies having patients 18 years of age or younger showed a relative risk of 0.23 with a 95 percent confidence interval of 0.02 to 2.46.

Figure J-57 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. In the trials with gabapentin as the newer agent, by Marson and colleages in 2007 provided relative risk of 1.65 with 95 percent confidence interval of 0.87 to 3.12. The second trial by Rowan and colleagues in 2005 provided a relative risk of 0.88 with a 95 percent confidence interval of 0.64 to 1.12. The third trial by Chadwick and colleagues in 1998 provided a relative risk of 0.52 with a 95 percent confidence interval of 0.15 to 1.80 for patients who received 300 milligrams of gabapentin, a relative risk of 1.13 with a 95 percent confidence interval of 0.40 to 3.46 for patients who received 900 milligrams of gabapentin and a relative risk of 1.10 with a 95 percent confidence interval of 0.93 to 3.37 for patients who received 1800 milligrams of gabapentin. The combined effect of the trails provided a relative risk of 0.98 with a 95 percent confidence interval of 0.75 to 1.28. In the trials with lamotrigine as the newer agent, the trial by Marson and colleages in 2007 provided relative risk of 1.07 with 95 percent confidence interval of 0.53 to 2.16. The second trial by Rowan and colleagues in 2005 provided relative risk of 0.85 with 95 percent confidence interval of 0.62 to 1.17. The third trial by Fakhoury and colleagues in 2004 provided a relative risk of 0.73 with a 95 percent confidence interval of 0.38 to 1.43. The fourth trial by Nieto-Barrera and colleagues in 2001 provided a relative risk of 0.82 with a 95 percent confidence interval of 0.47 to 1.43. The fifth trial by Brodie and colleagues in 1999 provided a relative risk of 0.59 with a 95 percent confidence interval of 0.26 to 1.38. The sixth trial by Reuanenen and colleagues in 1996 provided a relative risk of 0.61 with a 95 percent confidence interval of 0.22 to 1.68 for the patients receiving 100 milligrams of lamotrigine and a relative risk of 0.72 with a 95 percent confidence interval of 0.15 to 1.35. The seventh trial by Brodie and colleagues in 1995 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.40 to 1.29. The combined effect provided a relative risk of 0.79 with 95 percent confidence interval of 0.64 to 0.97. In the trials with oxcarbazepine as the newer agend by Donati and colleagues in 2007 provided a relative risk of 4.62 with a 95 percent confidence interval of 0.48 to 47.83. The second trial by Marson and colleagues in 2007 provided a relative risk of 1.67 and a 95 percent confidence interval of 0.81 to 3.43. The combined effect provided a relative risk of 1.78 with a 95 percent confidence interval of 0.87 to 3.36. In the trials with topiramate as the newer agent, the trial by Kang and colleagues in 2007 provided relative risk of 0.93 with 95 percent confidence interval of 0.10 to 8.79. The second trial by Marson and colleagues in 2007 provided a relative risk of 1.07 with a 95 percent confidence interval of 0.53 to 2.16. The third trial by Ramsay and colleagues in 2010 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.46 to 1.11. The fourth trial by Privitera and colleagues provided at relative risk of 0.49 with a 95 percent confidence interval of 0.22 to 1.11 for the patients who received 100 milligrams of topiramate and a relative risk of 0.47 with a 95 percent confidence interval of 0.21 to 1.10 for the patients who received 200 milligrams of topirmate. The fifth trial by Wheless and colleagues in 2004 provided a relative risk of 0.30 with a 95 percent confidence interval of 0.06 to 1.63 for patients who received 100 milligrams of topiramate and a relative risk of 0.29 with a 95 percent confidence interval of 0.06 to 1.59 for patients who received 200 milligrams of topiramate. The combined effect of topiramate provided a relative risk of 0.66 with a 95 percent confidence interval of 0.49 to 0.91. In the trials with vigabatrin as the newer agent, the trial by Chadwick and colleagues in 1999 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.62 to 1.62. In the second trial by Tanganelli in 1996 provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.58. The third trial by Kalviainen in 1995 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.11 to 1.10. The combined effect provided a relative risk of 0.78 with a 95 percent confidence interval of 0.67 to 0.91. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.78 with 95 percent confidence interval of 0.67 to 0.91. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.63 with a 95 percent confidence interval of 0.07 to 6.00, patients with new onset epilepsy showed a relative risk of 0.79 with 95 percent confidence interval of 0.66 to 0.94, patients with chronic epilepsy provided a relative risk of 0.73 with a 95 percent confidence interval of 0.38 to 1.43, trials enrolling more than 90 percent men showed a relative risk of 0.86 with a 95 percent confidence interval of 0.66 to 1.14, trials having patients 18 years of age or younger showed a relative risk of 0.35 with 95 percent confidence interval of 0.09 to 1.36, trials having patients 18 to 65 years of age showed a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.58, trials having patients 65 years of age or older showed a relative risk of 0.99 with a 95 percent confidence interval of 0.23 to 4.31.

Figure J-58 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational studies. In the studies with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 0.13 with 95 percent confidence interval of 0.01 to 1.24. In the studies with Levetiracetam as the newer agent, the study by Perry and colleages in 2008 provided relative risk of 0.15 with 95 percent confidence interval of 0.02 to 1.13. In studies with topiramate as the newer agent, studies by Ma and colleagues in 2009 provided relative risk of 0.42 with 95 percent confidence interval of 0.06 to 3.17 The combined effect of all newer AEDs showed a relative risk of 0.21 with 95 percent confidence interval of 0.05 to 0.89. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.15 with 95 percent confidence interval of 0.02 to 1.13, studies having patients with new onset epilepsy showed a relative risk of 0.21 with 95 percent confidence interval of 0.05 to 0.89, studies having patients 18 years of age or younger showed a relative risk of 0.25 with a 95 percent confidence interval of 0.05 to 1.33.

Figure J-59 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with controlled or sustained-release carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to controlled or sustained release of carbamazepine in clinical trials. The trial with lamotrigine as the newer agent, by Saetre and colleages in 2007 provided relative risk of 1.43with 95 percent confidence interval of 0.66 to 3.13. The trial with levetiracetam as the newer agent by Brodie and colleages in 2007 provided relative risk of 7.91 with 95 percent confidence interval of 2.97 to 21.31. The combined effect of all newer AEDs showed a relative risk of 3.26 with 95 percent confidence interval of 0.58 to18.52. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 3.26 with 95 percent confidence interval of 0.58 to 18.52, studies having patients 65 years of age or greater showed a relative risk of 1.43 with a 95 percent confidence interval of 0.66 to 3.13.

Figure J-60 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trial with lamotrigine as the newer agent, the trail by Steiner and colleages in 1999 provided relative risk of 0.80 with 95 percent confidence interval of 0.35 to 1.85. In the trials with Oxcarbazepine as the newer agent, the trial by Bill and colleages in 1997 provided relative risk of 0.85 with 95 percent confidence interval of 0.48 to 1.51. The second trial by Guerreiro and colleagues in 1997, provided relative risk of 0.42 with 95 percent confidence interval of 0.20 to 0.85. The combined effect of the two trials showed a relative risk of 0.62 with 95 percent confidence interval of 0.31 to 1.24. The combined effect of all newer AEDs showed a relative risk of 0.67 with 95 percent confidence interval of 0.43 to 1.05. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.67 with 95 percent confidence interval of 0.43 to 1.05, trials having patients 18 years of age or younger showed a relative risk of 0.42 with 95 percent confidence interval of 0.20 to 0.85.

Figure J-61 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 0.51 with 95 percent confidence interval of 0.07 to 3.78. In the trials with lamotrigine as the newer agent, the trial by Glauser and colleagues in 2010 provided a relative risk of 1.97 with a 95 percent confidence interval of 0.43 to 9.12. The trial by Morrell and colleages in 2008 provided relative risk of 1.12 with 95 percent confidence interval of 0.49 to 2.52. The trial by Marson and colleagues in 2007 provided a relative risk of 2.99 with a 95 percent confidence interval of 0.43 to 20.87. The trial by Fakhoury and colleagues provided a relative risk of 1.35 with a 95 percent confidence interval of 0.59 to 3.21. The trial by Biton and colleagues in 2003 provided relative risk of 1.48 with 95 percent confidence interval of 0.42 to 5.34. The trial by Biton and colleagues in 2001 provided a relataive risk of 1.22 with a 95 percent confidence interval of 0.45 to 3.31. The combined effect provided a relative risk of 1.34 with 95 percent confidence interval of 0.85 to 2.12. In the trials with topiramate as the newer agent, the trial by Levisohn and colleagues in 2007 provided a relative risk of 0.95 with a 95 percent confidence interval of 0.14 to 6.89 The trial by Marson and colleagues in 2007 provided a relative risk of 5.97 with a 95 percent confidence interval of 0.96 to 37.65. The trial by Privitera and colleagues in 2003 provided a relative risk of 0.48 with a 95 percent confidence interval of 0.19 to 1.24 for patients who received 100 mg of topiramate and a relative risk of 0.47 and a 95 percent confidence interval of 0.19 to 1.24 for patietns who received 200 milligrams of topiramate. The trial by Wheless and colleagues in 2004 provided at relative risk of 1.23 with a 95 percent confidence interval of 0.12 to 13.19 for the patients who received 100 milligrams of topiramate and a relative risk of 1.20 with a 95 percent cofifence interval of 0.12 to 13.19 for the patients who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.98 with a 95 percent confidence interval of 0.71 to 1.35. The combined effect of all newer AEDs showed a relative risk of 0.98 with 95 percent confidence interval of 0.71 to 1.35. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 1.59 with a 95 percent confidence interval of 0.48 to 5.28, patients with generalized epilepsy showed a relative risk of 1.52 with a 95 percent confidence interval of 0.39 to 5.87, patients with new onset epilepsy showed a relative risk of 1.15 with 95 percent confidence interval of 0.62 to 2.12, patients with chronic epilepsy showed a reltaive risk of 1.20 with a 95 percent confidence interval of 0.53 to 2.73, trials enrolling more than 90 percent women showed a relative risk of 1.12 with a 95 percent confidence interval of 0.63 to 10.58, trials having patients 18 years of age or younger showed a relative risk of 1.05 with 95 percent confidence interval of 0.91 to 1.21.

Figure J-62 Composite forest plot of meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of dizziness in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational studies. In the study with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 0.43 with 95 percent confidence interval of 0.04 to 5.17. In the study with topiramate as the newer agent, the study by Ma and colleages in 2009 provided relative risk of 0.55 with 95 percent confidence interval of 0.08 to 3.76. The combined effect of all newer AEDs showed a relative risk of 0.50 with 95 percent confidence interval of 0.08 to 3.18. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.50 with 95 percent confidence interval of 0.08 to 3.18, studies having patients 18 years of age or younger showed a relative risk of 0.55 with 95 percent confidence interval of 0.08 to 3.76.

Figure J-63 Composite forest plot of meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. The trial with gabapentin as the newer agent by Marson and colleagues in 2007 provided a relative risk of 0.78 with a 95 percent confidence interval of 0.30 to 2.00. In the trials with lamotrigine as the newer agent, the trial by Marson and colleages in 2007 provided relative risk of 1.00 with 95 percent confidence interval of 0.41 to 2.42. The second trail by Fakhoury and colleages in 2004 provided relative risk of 0.12 with 95 percent confidence interval of 0.02 to 0.76. The third trial by Reuanen and colleagues in 1996 provided a relative risk of 0.79 with a 95 pecent confidence interval of 0.27 to 2.37 for patients who received 100 milligrams of lamotrigine and a relative risk of 0.82 with a 95 percent confidence interval of 0.28 to 2.45 for patients who received 200 milligrams of lamotrigine. The fourth trial by Brodie and colleagues in 1995 provided a relative risk of 1.42 with a 95 percent confidence interval of 0.79 to 2.54. The combined effect of the two trials showed a relative risk of 0.95 with 95 percent confidence interval of 0.56 to 1.60. In the trials with oxcarbazepine as the newer agent, the trial by Marson and colleagues in 2007 provided a relative risk of 3.00 with a 95 percent confidence interval of 1.36 to 6.60. The trial by Reinikainen and colleagues in 1987 provided a realtive risk of 037 with a 95 percetn confidence interval of 0.03 to 4.26. The combined effect provided a relative risk of 1.87 with a 95 percent confidence interval of 0.34 to 10.40. In the trials with topriamate as the newer agent, the trial by Marson and colleagues provided a relative risk of 0.44 with a 95 percent confidenc interval of 0.15 to 1.35. The trial by Privateral and colleagues provided a relative risk of 0.36 with a 95 percent conficend interval of 0.18 to 0.72 for patients that received 100 milligrams of topiramate and a relative risk of 0.30 with a 95 percent confidence interval of 0.40 to 1.31 for patients who received 200 milligrams of topiramate. The trial by Wheless and colleages in 2004 provided relative risk of 0.30 with 95 percent confidence interval of 0.06 to 1.59 for patients who received 100 milligrams of topiramate and a relative risk of 0.29 with a 95 percent confidence interval of 0.06 to 1.59 in patients that received 200 milligrams of topiramate. The combined effect of the trials showed a relative risk of 0.49 with 95 percent confidence interval of 0.33 to 1.02. The trial with vigabatrin as the newer agent provided a relative risk of 0.24 with a 95 percent confidence interval of 0.04 to 1.47. The combined effect of all newer AEDs showed a relative risk of 0.69 with 95 percent confidence interval of 0.46 to 1.02. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.24 with a 95 percetn cofidence interval of 0.04 to 1.47, patients with new onset epilepsy showed a relative risk of 0.56 with 95 percent confidence interval of 0.19 to 1.65, patients with chronic epilepsy showed a relative risk of 0.17 to 0.03 to 1.01, trials having patients 18 years of age or younger showed a relative risk of 0.30 with 95 percent confidence interval of 0.08 to 1.10, trials having patients 18 to 65 years of age showed a relative risk of 0.24 with a 95 percent confidence interval of 0.04 to 1.47.

Figure J-64 Composite forest plot of meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trial with lamotrigine as the newer agent, the study by Steiner and colleages in 1999 provided relative risk of 1.93 with 95 percent confidence interval of 0.63 to 6.02. In the trials with Oxcarbazepine as the newer agent, the trial by Bill and colleages in 1997 provided relative risk of .85 with 95 percent confidence interval of 0.43 to 1.67. The second trial by Guerreiro and colleagues in 1997 provided relative risk of 0.70 with 95 percent confidence interval of 0.24 to 2.02. The combined effect of the two trials showed a relative risk of 0.80 with 95 percent confidence interval of 0.45 to 1.45. In the trial with topiramate as the newer agent, the trial by Ramsay and colleagues in 2007 provided relative risk of 0.72 with 95 percent confidence interval of 0.32 to 1.62. The combined effect of all newer AEDs showed a relative risk of 0.88 with 95 percent confidence interval of 0.56 to 1.37. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.95 with 95 percent confidence interval of 0.56 to 1.62.

Figure J-65 Composite forest plot of meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of nausea in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 0.34 with 95 percent confidence interval of 0.03 to 4.04. In the trials with lamotrigine as the newer agent, the trial by Glauser and colleages in 2010 provided relative risk of 0.20 with 95 percent confidence interval of 0.05 to 0.78. The second trial by Morrell and colleagues in 2008 provided a relative risk of 0.19 with a 95 percetn confidence interval of 0.06 to 0.60. The third trial by Marson and colleagues in 2007 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.28 to 3.60. The fourth trial by Fakhoury and colleagues in 2004 provided a relative risk of 0.43 with a 95 percent confidence interval of 0.16 to 1.18. The fifth trial by Biton and colleagues in 2003 provided relative risk of 1.48 with 95 percent confidence interval of 0.42 to 5.34. The sixth trial by Biton and colleagues in 2001 provided a relataive risk of 0.52 with a 95 percent confidence interval of 0.24 to 1.11. The combined effect provided a relative risk of 0.48 with 95 percent confidence interval of 0.27 to 0.86. The trial with oxcarbazepine as the newer agent by Christie and colleagues in 1997 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.36 to 1.54. In the trials with topiramate as the newer agent, the trial by Levisohn and colleagues in 2007 provided a relative risk of 0.16 with a 95 percent confidence interval of 0.02 to 0.98. The trial by Marson and colleagues provided a relative risk of 0.50 with a 95 percent confidence interval of 0.11 to 2.30. The trial by Privitera and colleagues in 2003 provided a relative risk of 0.51 with a 95 percen confidence interval of 0.22 to 1.26 for patients receiving 100 milligrams of topiramate. The trial by Privitera and colleagues in 2003 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.46 to 2.34 for patietns receiving 200 milligrams of topiramate. The trial by Wheless and colleagues in 2004 provided at relative risk of 0.50 with a 95 percent confidence interval of 0.07 to 3.71 for the patients who received 100 milligrams of topiramate. The trial by Wheless and colleagues in 2004 provided a relative risk of 0.49 with a 95 percent cofifence interval of 0.07 to 3.61 for the patietns who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.61 with a 95 percent confidence interval of 0.36 to 1.04. The combined effect of all newer AEDs showed a relative risk of 0.56 with 95 percent confidence interval of 0.41 to 0.77. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.34 with a 95 percent confidence interval of 0.03 to 4.04, patients with generalized epilepsy showed a relative risk of 0.18 with a 95 percent confidence interval of 0.05 to 0.62, patients with new onset epilepsy showed a relative risk of 0.56 with 95 percent confidence interval of 0.30 to 1.04, patients with chronic epilepsy showed a reltaive risk of 0.42 with a 95 percent confidence interval of 0.16 to 1.14, trials enrolling more than 90 percent women showed a relative risk of 0.19 with a 95 percent confidence interval of 0.06 to 0.60, trials having patients 18 years of age or younger showed a relative risk of 0.55 with 95 percent confidence interval of 0.20 to 1.52.

Figure J-66 Composite forest plot of meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. In the trials with lamotrigine as the newer agent, the trail by Brodie and colleages in 1999 provided relative risk of 1.41 with 95 percent confidence interval of 0.44 to 4.71. The second trail by Brodie and colleages in 1995 provided relative risk of 1.31 with 95 percent confidence interval of 0.59 to 2.95. The combined effect of the two trials showed a relative risk of 1.34 with 95 percent confidence interval of 0.67 to 2.68. In the trials with topiramate as the newer agent, the trial by Wheless and colleages in 2004a provided relative risk of 1.21 with 95 percent confidence interval of 0.21 to 7.83. The second trial by Wheless and colleagues in 2004b provided relative risk of 0.59 with 95 percent confidence interval of 0.09 to 4.38. The combined effect of the two trials showed a relative risk of 0.88 with 95 percent confidence interval of 0.19 to 4.12. The combined effect of all newer AEDs showed a relative risk of 1.25 with 95 percent confidence interval of 0.66 to 2.35. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 1.25 with 95 percent confidence interval of 0.66 to 2.35, trials having patients 18 years of age or younger showed a relative risk of 0.88 with 95 percent confidence interval of 0.19 to 4.12, trials having patients 65 years of age or greater showed a relative risk of 1.41 with a 95 percent confidence interval of 0.44 to 4.71.

Figure J-67 Composite forest plot of meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trials with oxcarbazepine as the newer agent, the trail by Guerreiro and colleages in 1997 provided relative risk of 0.09 with 95 percent confidence interval of 0.01 to 0.89. The combined effect of all newer AEDs showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 0.89. In the subgroup analysis, trials having patients 18 years of age or younger showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 0.89.

Figure J-68 Composite forest plot of meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of vomiting in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 1.03 with 95 percent confidence interval of 0.19 to 5.61. In the trials with lamotrigine as the newer agent, the trial by Morrell and colleages in 2005 provided relative risk of 0.38 with 95 percent confidence interval of 0.16 to 0.92. The second trial by Biton and colleagues in 2003 provided relative risk of 4.44 with 95 percent confidence interval of 0.75 to 28.28. The third trial by Biton and colleagues in 2001 provided a relataive risk of 0.46 with a 95 percent confidence interval of 0.16 to 1.35. The combined effect provided a relative risk of 0.66 with 95 percent confidence interval of 0.22 to 2.00. In the trials with topiramate as the newer agent, the trial by Wheless and colleagues in 2004 provided at relative risk of 2.22 with a 95 percent confidence interval of 0.26 to 22.85 for the patients who received 100 milligrams of topiramate. The trial by Wheless and colleagues in 2004 provided a relative risk of 1.20 with a 95 percent cofifence interval of 0.12 to 13.19 for the patietns who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.38 with a 95 percent confidence interval of 0.24 to 0.59. In the trials with vigabatrin as the newer agent, the trial by Chadwick and colleagues in 1999 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.14 to 0.71. The combined effect provided a relative risk of 1.65 with a 95 percent confidence interval of 0.21 to 12.79. The combined effect of all newer AEDs showed a relative risk of 0.69 with 95 percent confidence interval of 0.34 to 1.42. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 1.03 with a 95 percent confidence interval of 0.19 to 5.61, patients with new onset epilepsy showed a relative risk of 1.65 with 95 percent confidence interval of 0.21 to 12.79, patients with chronic epilepsy showed a reltaive risk of 1.03 with a 95 percent confidence interval of 0.19 to 5.61, trials enrolling more than 90 percent women showed a relative risk of 0.38 with a 95 percent confidence interval of 0.16 to 0.92, trials having patients 18 years of age or younger showed a relative risk of 1.65 with 95 percent confidence interval of 0.21 to 12.79.

Figure J-69 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. In the trials with gabapentin as the newer agent, by Marson and colleages in 2007 provided relative risk of 0.34 with 95 percent confidence interval of 0.19 to 0.63. The second trial by Rowan and colleagues in 2005 provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.57. The combinded effect of the two trails provided a relative risk of 0.31 with a 95 percent confidence interval of 0.14 to 0.69. In the trials with lamotrigine as the newer agent, the trial by Marson and colleages in 2007 provided relative risk of 0.45 with 95 percent confidence interval of 0.26 to 0.77. The second trial by Rowan and colleagues in 2005 provided relative risk of 0.16 with 95 percent confidence interval of 0.03 to 0.97. The third trial by Nieto-Barrera and colleagues in 2001 provided a raltaive risk of 1.00 with a 95 percent confidence interval of 0.61 to 1.66. The fourth trial by Brodie and colleagues in 1999 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.16 to 0.77. The fifth trial by Reuanenen and colleagues in 1996 provided a relative risk of 0.61 with a 95 percent confidence interval of 0.21 to 1.83 for the patients receiving 100 milligrams of lamotrigine and a relative risk of 0.95 with a 95 percent confidence interval of 0.35 to 2.62. The sixth trial by Brodie and colleagues in 1995 provided a relative risk of 0.99 with a 95 percent confidence interval of 0.60 to 1.16. The combined effect provided a relative risk of 0.66 with 95 percent confidence interval of 0.46 to 0.94. In the trials with oxcarbazepine as the newer agend by Donati and colleagues in 2007 provided a relative risk of 0.68 with a 95 percent confidence interval of 0.18 to 2.60. The second trial by Marson and colleagues in 2007 provided a relative risk of 0.95 and a 95 percent confidence interval of 0.57 to 1.57. The combined effect provided a relative risk of 0.91 with a 95 percent confidence interval of 0.56 to 1.48. In the trials with topiramate as the newer agent, the trial by Kang and colleagues in 2007 provided relative risk of 0.12 with 95 percent confidence interval of 0.02 to 0.68. The second trial by Marson and colleagues in 2007 provided a relative risk of 0.45 with a 95 percent confidence interval of 0.26 to 0.77. The third trial by Privitera and colleagues provided at relative risk of 0.36 with a 95 percent confidence interval of 0.12 to 1.09 for the patients who received 100 milligrams of topiramate. The trial by Privitera and colleagues in 2003 provided a relative risk of 0.25 with a 95 percent cofifence interval of 0.08 to 0.85 for the patietns who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.38 with a 95 percent confidence interval of 0.24 to 0.59. In the trials with vigabatrin as the newer agent, the trial by Chadwick and colleagues in 1999 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.14 to 0.71. In the second trial by Tanganelli in 1996 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.03 to 3.74. In the third trial by Kalviainen in 1995 provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.66. The combined effect provided a relative risk of 0.29 with a 95 percent confidence interval of 0.13 to 0.62. The combined effect of all newer AEDs showed a relative risk of 0.52 with 95 percent confidence interval of 0.39 to 0.69. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.49 with a 95 percent confidence interval of 0.23 to 1.05, patients with new onset epilepsy showed a relative risk of 0.45 with 95 percent confidence interval of 0.26 to 0.77, trials enrolling more than 90 percent men showed a relative risk of 0.12 with a 95 percent confidence interval of 0.02 to 0.69, trials having patients 18 years of age or younger showed a relative risk of 0.54 with 95 percent confidence interval of 0.19 to 1.52, trials having patients 18 to 65 years of age showed a relative risk of 0.32 with a 95 percent confidence interval of 0.03 to 3.47, trials having patients 65 years of age or older showed a relative risk of 0.67 with a 95 percent confidence interval of 0.15 to 2.90.

Figure J-70 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in observational studies

AEDs=antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in observational studies. In the studies with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 0.37 with 95 percent confidence interval of 0.12 to 1.11. In the studies with Levetiracetam as the newer agent, the study by Perry and colleages in 2008 provided relative risk of 0.93 with 95 percent confidence interval of 0.08 to 11.16. In the trials with Oxcarbazepine as the newer agent, the trial by Clemens and colleages in 2004 provided relative risk of 3.00 with 95 percent confidence interval of 0.26 to 35.71. In the studies with topiramate as the newer agent, the study by Kim and colleages in 2009 provided relative risk of 0.28 with 95 percent confidence interval of 0.03 to 2.81. The second trail by Ma and colleages in 2009 provided relative risk of 0.06 with 95 percent confidence interval of 0.01 to 0.32. The combined effect of the two trials showed a relative risk of 0.10 with 95 percent confidence interval of 0.02 to 0.49. The combined effect of all newer AEDs showed a relative risk of 0.33 with 95 percent confidence interval of 0.10 to 1.05. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.24 with 95 percent confidence interval of 0.06 to 1.03, studies in patients 18 years of age or younger showed a relative risk of 0.17 with a 95 percent confidence interval of 0.03 to 0.91.

Figure J-71 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with controlled- or sustained-release carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to controlled or sustained release of carbamazepine in clinical trials. In the studies with lamotrigine as the newer agent, the study by Saetre and colleages in 2007 provided relative risk of 0.41 with 95 percent confidence interval of 0.16 to 1.07. In the studies with Levetiracetam as the newer agent, the study by Brodie and colleages in 2007 provided relative risk of 0.51 with 95 percent confidence interval of 0.23 to 1.15. The combined effect of all newer AEDs showed a relative risk of 0.47 with 95 percent confidence interval of 0.25 to 0.89. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.47 with 95 percent confidence interval of 0.25 to 0.89, studies having patients 65 years of age or greater showed a relative risk of 0.41 with a 95 percent confidence interval of 0.16 to 1.07.

Figure J-72 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trial with lamotrigine as the newer agent, the study by Steiner and colleages in 1999 provided relative risk of 1.47 with 95 percent confidence interval of 0.67 to 3.26. In the trials with Oxcarbazepine as the newer agent, the trial by Bill and colleages in 1997 provided relative risk of .78 with 95 percent confidence interval of 0.39 to 1.57. The second trial by Guerreiro and colleagues in 1997 provided relative risk of 0.78 with 95 percent confidence interval of 0.23 to 2.62. The combined effect of the two trials showed a relative risk of 0.78 with 95 percent confidence interval of 0.42 to 1.46. In the trial with topiramate as the newer agent, the trial by Ramsay and colleagues in 2007 provided relative risk of 0.10 with 95 percent confidence interval of 0.02 to0.57. The combined effect of all newer AEDs showed a relative risk of 0.76 with 95 percent confidence interval of 0.34 to 1.66. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.99 with 95 percent confidence interval of 0.60 to 1.62, trials having patients 18 years of age or younger showed a relative risk of 0.78 with 95 percent confidence interval of 0.23 to 2.62.

Figure J-73 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in clinical trials. The trial with felbamate as the newer agent, by Faught and colleages in 1993 provided relative risk of 1.03 with 95 percent confidence interval of 0.11 to 9.62. In the trials with lamotrigine as the newer agent, the trial by Kwan and colleages in 2009 provided relative risk of 10.44 with 95 percent confidence interval of 1.05 to 107.83. The second trial by Morrell and colleagues in 2008 provided relative risk of 1.13 with 95 percent confidence interval of 0.48 to 2.65. The third trial by Marson and colleagues in 2007 provided a raltaive risk of 6.47 with a 95 percent confidence interval of 1.66 to 25.50. The fourth trial by Steinhoff and colleagues in 2005 provided a relative risk of 8.19 with a 95 percent confidence interval of 0.84 to 84.41. The fifth trial by Coppola and colleagues provided a relative risk of 3.00 with a 95 percent confidence interval of 0.26 to 35.67. The sixth trial by Biton and colleagues in 2003 provided a relative risk of 1.11 with a 95 percent confidence interval of 0.12 to 10.19. The combined effect provided a relative risk of 2.69 with 95 percent confidence interval of 1.07 to 6.77. The trial with oxcarbazepine as the newer agend by Donati and colleagues in 2007 provided a relative risk of 4.87 with a 95 percent confidence interval of 0.49 to 49.52. In the trials with topiramate as the newer agent, the trial by Levisohn and colleagues in 2007 provided relative risk of 0.10 with 95 percent confidence interval of 0.01 to 0.99. The second trial by Marson and colleagues in 2007 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.07 to 3.78. The third trial by Privitera and colleagues provided at relative risk of 0.45 with a 95 percent confidence interval of 0.12 to 1.72 for the patients who received 100 milligrams of topiramate. The trial by Privitera and colleagues in 2003 provided a relative risk of 0.31 with a 95 percent cofifence interval of 0.08 to 1.32 for the patietns who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.35 with a 95 percent confidence interval of 0.14 to 0.86. The combined effect of all newer AEDs showed a relative risk of 1.17 with 95 percent confidence interval of 0.55 to 2.48. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 2.13 with a 95 percent confidence interval of 0.29 to 15.49, patients with generalized epilepsy showed a relative risk of 1.33 with 95 percent confidence interval of 0.09 to 19.38, patients with new onset epilepsy showed a reltative risk of 5.04 with a 95 percent confidence interval of 0.91 to 27.84, trials enrolling more than 90 percent women showed a relative risk of 1.13 with a 95 percent confidence interval of 0.48 to 2.65 and trials having patients 18 years of age or younger showed a relative risk of 3.86 with 95 percent confidence interval of 0.46 to 32.34.

Figure J-74 Composite forest plot of meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in observational studies

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of skin rash in patients with epilepsy taking newer antiepileptic drugs compared to valproic acid in observational studies. In the study with lamotrigine as the newer agent, the study by Kwan and colleages in 2001 provided relative risk of 9.05 with 95 percent confidence interval of 0.86 to 96.19. In the study with topiramate as the newer agent, the study by Ma and colleages in 2009 provided relative risk of 0.0.82 with 95 percent confidence interval of 0.11 to 6.19. The combined effect of all newer AEDs showed a relative risk of 2.33 with 95 percent confidence interval of 0.22 to 25.11. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 2.33 with 95 percent confidence interval of 0.22 to 25.11, studies having patients 18 years of age or younger showed a relative risk of 0.82 with 95 percent confidence interval of 0.11 to 6.19.

Figure J-75 Composite forest plot of meta-analysis of alopecia in patients with epilepsy taking newer antiepileptic drugs compared with carbamazepine in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of alopecia in patients with epilepsy taking newer antiepileptic drugs compared to carbamazepine in clinical trials. The trial with lamotrigine as the newer agent, by Fakhoury and colleages in 2004 provided relative risk of 1.41 with 95 percent confidence interval of 0.21 to 9.73. In the trials with Oxcarbazepine as the newer agent, the trial by Donati and colleages in 1997 provided relative risk of 0.17 with 95 percent confidence interval of 0.01 to 2.04. The second trial by Dam and colleagues in 1989 provided relative risk of 0.21 with 95 percent confidence interval of 0.02 to 2.33. The combined effect of the two trials procideded a relative risk of 0.19 with 95 percent confidence interval of 0.02 to 1.71. In the trials with topiramate as the newer agent, the trial by Wheless and colleagues in 2004 provided relative risk of 0.16 with 95 percent confidence interval of 0.01 to 2.05 for the patients who received 100 milligrams of topiramte. The trial by Wheless and colleagues in 2004 provided a relative risk of 0.15 with a 95 percent confidence interval of 0.01 to 2.00 for the patients who received 200 milligrams of topiramate. The second trial by Privitera and colleagues provided at relative risk of 1.20 with a 95 percent confidence interval of 7.94 for the patients who received 100 milligrams of topiramate. The trial by Priviterat and colleagues provided a relative risk of 0.63 with a 95 percent cofifence interval of 0.08 to 4.81 for the patietns who received 200 milligrams of topirmate. The combined effect of topiramate provided a relative risk of 0.51 with a 95 percent confidence interval of 0.14 to 1.93. In the trials with vigabatrin as the newer agent, the trial by Kalviainen and colleagues in 1995 provided a relative risk of 3.14 with a 95 percent confidence interval of 0.26 to 37.78. The combined effect of all newer AEDs showed a relative risk of 0.60 with 95 percent confidence interval of 0.23 to 1.58. In the subgroup analysis, patients with partial epilepsy showed a relative risk of 0.17 with a 95 percent confidence interval of 0.01 to 2.04, patients with new onset epilepsy showed a relative risk of 0.16 with 95 percent confidence interval of 0.02 to 1.06, patients with chronic epilepsy showed a reltative risk of 1.84 with a 95 percent confidence interval of 0.30 to 11.43, trials having patients 18 years of age or younger showed a relative risk of 0.16 with 95 percent confidence interval of 0.02 to 1.06.

Figure J-76 Composite forest plot of meta-analysis of gum hyperplasia in patients with epilepsy taking oxcarbazepine compared with phenytoin in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of gum hyperplasia in patients with epilepsy taking newer antiepileptic drugs compared to phenytoin in clinical trials. In the trials with oxcarbazepine as the newer agent, the study by Bill and colleages in 1997 provided relative risk of 0.12 with 95 percent confidence interval of 0.03 to 0.44. The second trial by Guerreiro and colleagues in 1997 provided relative risk of 0.08 with 95 percent confidence interval of 0.02 to 0.30. The combined effect of the two trials showed a relative risk of 0.10 with 95 percent confidence interval of 0.04 to 0.27. The combined effect of all newer antiepileptic drugs showed a relative risk of 0.10 with 95 percent confidence interval of 0.04 to 0.27. In the subgroup analysis, patients with new onset epilepsy showed a relative risk of 0.10 with 95 percent confidence interval of 0.04 to 0.27, trials having patients 18 years of age or younger showed a relative risk of 0.08 with 95 percent confidence interval of 0.02 to 0.30.

Figure J-77 Composite forest plot of meta-analysis of alopecia in patients with epilepsy taking newer antiepileptic drugs compared with valproic acid in controlled clinical trials

AEDs = antiepileptic drugs

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value. Lowercase letters represent study arms within the same trial.

This figure depicts the meta-analysis of the incicence of alopecia in patients with epilepsy taking newer antiepileptic drugs compared to valproic aicd in controlled clinical trials. In the trials with gabapentin as the newer agent, the first trial by Marson and colleagues in 2007 provided a relative risk of 1.06 with 95 percent confidence interval of 0.57 to 1.97. The second trial by Rowan and colleagues in 2005 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.36 to 1.55. The combined effect of the two trials showed a relative risk of 0.92 with 95 percent confidence interval of 0.57 to 1.48. In the trials with lamtorigine as the newer agent, the first trial by Marson and colleage in 2007 provided relative risk of 0.67 with 96 percent confidence interval of 0.33 to 1.34. The second trial by Rowan and colleague in 2005 provided relative risk of 0.53 with 95 percent confidence interval of 0.23 to 1.19. The third trial by Fakhoury and colleagues in 2004 provided a relative risk of 2.36 with a 95 percent confidence interval of 0.22 to 26.14. The fourth trial by Brodie and colleaguesin 1999 provided a relative risk of 0.01 with a 95 percent confidence interval of 0.009 to 1.04. The fifth and sixth trial by Reunanen and colleagues in 1996 provided a relative risk of 1.53 and 1.59 with a 95 percent confidence interval of 0.3 to 18.56 and 0.13 to 19.22, respectively. The combined effect of the six trials showed a relative risk of 0.63 with 95 percent confidence interval of 0.37 to 1.04. A single trial with oxcarbazepine as the newer agent by Marson and colleage in 2007 provided a relative risk of 0.50 with 95 percent confidence interval of 0.19 to 1.27. A single trial with topiramate as the newer agent by Marson and colleague in 2007 provided a relative risk of 0.94 with 95 percent confidence interval of 0.50 to 1.78. A single trial with vigabatrin as the newer agent by Chadwick and colleague in 1999 provided a relative risk of 2.01 with 95 percent confidence interval of 0.26 to 15.27. The combined effect of all newer AEDs showed a relative risk of 0.75 with 95 percent confidence interval of 0.51 to 1.12. In the subgroup analysis, trials having patients with new onset epilepsy showed a relative risk of 0.63 with 95 percent confidence interval of 0.34 to 1.18, trials having patients with chronic epilepsy showed a relative risk of 2.36 with 95 percent confidence interval of 0.22 to 26.14, trials having greater than 90 percent males showed a relative risk of 0.64 with 95 percent confidence interval of 0.33 to 1.23, and trials having patients 65 years or older showed a relative risk of 0.09 with 95 percent confidence interval of 0.01 to 1.04.