# Applicability of Indivual Studies and the Body of Evidence

Table I-1 Evaluation of applicability for individual studies for innovator versus generic antiepileptic drug evaluation

Table I-2 Strength of applicability for individual studies comparing older versus newer antiepileptic drugs

Table I-3 Applicability rating for final outcome evaluations for innovator versus generic antiepileptic drugs under Key Question 1

Table I-4 Applicability rating for medical service utilization for innovator versus generic antiepileptic drugs under Key Question 1

Table I-5 Applicability rating for health related quality of life for innovator versus generic antiepileptic drugs under Key Question 1

Table I-6 Applicability rating for final health outcomes for innovator versus generic antiepileptic drugs Key Question 1

Table I-7 Applicability rating for withdrawals due to adverse events for innovator versus generic antiepileptic drugs in key question 1

Table I-8 Applicability rating for pharmacokinetic effects for innovator versus generic antiepileptic drugs Key Question 2

Table I-9 Applicability rating for neurologic adverse events for innovator versus generic antiepileptic drugs in key question 3

Table I-10 Applicability rating for incidence of adverse events and other outcomes for innovator versus generic antiepileptic drugs in Key Question 3

Table I-11 Strength of applicability for the body of evidence evaluating mortality for older versus newer antiepileptic drugs

Table I-12 Strength of applicability for medical service utilization for older versus newer antiepileptic drugs

Table I-13 Strength of applicability for health related quality of life for older versus newer antiepileptic drugs

Table I-14 Strength of applicability for final health outcomes for older versus newer antiepileptic drugs

Table I-15 Strength of applicability for withdrawals due to adverse events for older versus newer antiepileptic drugs

Table I-16 Strength of applicability for neurologic adverse events for newer versus older antiepileptic drugs

Table I-17 Strength of applicability for incidence of adverse events for older versus newer antiepileptic drugs

Table I-18 Strength of applicability for bone mineral density for older versus newer antiepileptic drugs

Table I-19 Strength of applicability for cosmetic adverse effects for older versus newer antiepileptic drugs