# Strength of Evidence for Outcomes

Table H-1 Strength of evidence for final outcome evaluations for innovator versus generic antiepileptic drugs under Key Question 1

Table H-2 Strength of evidence for medical service utilization for innovator versus generic antiepileptic drugs under Key Question 1

Table H-3 Strength of evidence for health related quality of life for innovator versus generic antiepileptic drugs under Key Question 1

Table H-4 Strength of evidence for final health outcomes for innovator versus generic antiepileptic drugs Key Question 1

Table H-5 Strength of evidence for withdrawals due to adverse events for innovator versus generic antiepileptic drugs in Key Question 1

Table H-6 Strength of evidence for pharmacokinetic effects for innovator versus generic antiepileptic drugs Key Question 2

Table H-7 Strength of evidence for incidence of adverse events for innovator versus generic antiepileptic drugs in Key Question 3

Table H-8 Strength of evidence for final outcome evaluations for older versus newer antiepileptic drugs under key question 1

Table H-9 Strength of evidence for medical service utilization for older versus newer antiepileptic drugs under key question 1

Table H-10 Strength of evidence for health related quality of life for older versus newer antiepileptic drugs under key question 1

Table H-11 Strength of evidence for final health outcomes for olderer versus newer antiepileptic drugs key question 1

Table H-12 Strength of evidence for withdrawals due to adverse events for older versus newer antiepileptic drugs in key question 1

Table H-13 Strength of evidence for neurologic adverse events for older versus newer antiepileptic drugs in Key Question 3

Table H-14 Strength of evidence for incidence of adverse events for older versus newer antiepileptic drugs in key question 3

Table H-15 Strength of evidence for cognition and mood for older versus newer antiepileptic drugs in Key Question 3

Table H-16 Strength of evidence for bone mineral density for older versus newer antiepileptic drugs in key question 3

Table H-17 Strength of evidence for cosmetic adverse effects for older versus newer antiepileptic drugs Key Question 3