# Additional Evidence Tables

Table G-1 Seizure outcomes in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-2 Withdrawals and discontinuations in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-3 Final health outcomes in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-4 Secondary seizure injury in controlled studies comparing innovator versus generic antiepielptic drugs

Table G-5 Change from baseline in health-related quality of life in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-6 Pharmacokinetic outcomes in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-7 Adverse events in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-8 Neurological adverse events in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-9 Mood and cognition effects in controlled studies comparing innovator versus generic antiepileptic drugs

Table G-10 Seizure outcomes in studies comparing older versus newer antiepileptic drugs

Table G-11 Seizure outcomes in studies comparing older versus newer antiepileptic drugs

Table G-12 Withdrawals and discontinuations in studies comparing older versus newer antiepileptic drugs

Table G-13 Final health outcomes in studies comparing older versus newer antiepileptic drugs

Table G-14 Health-related quality of life for studies comparing older versus newer antiepileptic drugs

Table G-15 Adverse events in studies comparing older versus newer antiepileptic drugs

Table G-16 Neurological adverse events in studies comparing older versus newer antiepileptic drugs

Table G-17 Cosmetic adverse effects in studies comparing older versus newer antiepileptic drugs

Table G-18 Change in bone mineral density from baseline in studies comparing older versus newer antiepileptic drugs

Table G-19 Change in bone mineral density Z score in studies comparing older versus newer antiepileptic drugs

Table G-20 Serious adverse events for individual antiepileptic drugs