# Baseline Characteristics for Included Studies and Trials

Table F-1 Study design and populations of controlled studies comparing innovator versus generic antiepileptic drugs

Table F-2 Baseline characteristics of controlled studies comparing innovator versus generic antiepileptic drugs

Table F-3 Baseline characteristics of controlled studies comparing innovator versus generic antiepileptic drugs

Table F-4 Prior or concurrent AED use in controlled studies comparing innovator versus generic antiepileptic drugs

Table F-5 Study design and populations of studies comparing older versus newer antiepileptic drugs

Table F-6 Inclusion and exclusion criteria of studies comparing older versus newer antiepileptic drugs

Table F-7 Baseline characteristics of studies comparing older versus newer antiepileptic drugs

Table F-8 Epilepsy history and seizure type for studies comparing older versus newer antiepileptic drugs

Table F-9 Prior or concurrent antiepileptic drug use in studies comparing newer versus older antiepileptic drugs

## References for Evidence Tables

Aldenkamp AP, Baker G, Mulder OG, et al. A multicenter, randomized clinical study to evaluate the effect on cognitive function of topiramate compared with valproate as add-on therapy to carbamazepine in patients with partial-onset seizures. Epilepsia. 2000;41:1167-78. [pmid: 10999556].
Aldenkamp AP, Rentmeester T, Hulsman J, et al. Pharmacokinetics and cognitive effects of carbamazepine formulations with different dissolution rates. Eur J Clin Pharmacol. 1998;54:185-92. [pmid: 9626926].
Andermann F, Duh MS, Gosselin A, et al. Compulsory generic switching of antiepileptic drugs: high switchback rates to branded compounds compared with other drug classes. Epilepsia. 2007;48:464-9. [pmid: 17346246].
Babayigit A, Dirik E, Bober E, et al. Adverse effects of antiepileptic drugs on bone mineral density. Pediatr Neurol. 2006;35:177-81. [pmid: 16939856].
Bill PA, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in adults with previously untreated epilepsy. Epilepsy Res. 1997;27:195-204. [pmid: 9237054].
Biton V, Levisohn P, Hoyler S, et al. Lamotrigine versus valproate monotherapy-associated weight change in adolescents with epilepsy: results from a post hoc analysis of a randomized, double-blind clinical trial. J Child Neurol. 2003;18:133-9. [pmid: 12693782].
Biton V, Mirza W, Montouris G, et al. Weight change associated with valproate and lamotrigine monotherapy in patients with epilepsy. Neurology. 2001;56:172-7. [pmid: 11160951].
Brodie MJ, Mumford JP. Double-blind substitution of vigabatrin and valproate in carbamazepine-resistant partial epilepsy. 012 Study group. Epilepsy Res. 1999;34:199-205. [pmid: 10210035].
Brodie MJ, Overstall PW, Giorgi L. Multicentre, double-blind, randomised comparison between lamotrigine and carbamazepine in elderly patients with newly diagnosed epilepsy. The UK Lamotrigine Elderly Study Group. Epilepsy Res. 1999;37:81-7. [pmid: 10515178].
Brodie MJ, Perucca E, Ryvlin P, et al. Comparison of levetiracetam and controlled-release carbamazepine in newly diagnosed epilepsy. Neurology. 2007;68:402-8. [pmid: 17283312].
Brodie MJ, Richens A, Yuen AW. Double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy. UK Lamotrigine/Carbamazepine Monotherapy Trial Group. Lancet. 1995;345:476-9. [pmid: 7710545].
Chadwick D. Safety and efficacy of vigabatrin and carbamazepine in newly diagnosed epilepsy: a multicentre randomised double-blind study. Vigabatrin European Monotherapy Study Group. Lancet. 1999;354:13-9. [pmid: 10406359].
Chadwick DW, Anhut H, Greiner MJ, et al. A double-blind trial of gabapentin monotherapy for newly diagnosed partial seizures. International Gabapentin Monotherapy Study Group 945-77. Neurology. 1998;51:1282-8. [pmid: 9818846].
Chen SS, Allen J, Oxley J, et al. Comparative bioavailability of phenytoin from generic formulations in the United Kingdom. Epilepsia. 1982;23:149-52. [pmid: 7075570].
Christe W, Kramer G, Vigonius U, et al. A double-blind controlled clinical trial: oxcarbazepine versus sodium valproate in adults with newly diagnosed epilepsy. Epilepsy Res. 1997;26:451-60. [pmid: 9127726].
Clemens B, Menes A, Nagy Z. Objective assessment of neurotoxicity while shifting from carbamazepine to oxcarbazepine. Acta Neurol Scand. 2004;109:324-9. [pmid: 15080858].
Coppola G, Auricchio G, Federico R, et al. Lamotrigine versus valproic acid as first-line monotherapy in newly diagnosed typical absence seizures: an open-label, randomized, parallel-group study. Epilepsia. 2004;45:1049-53. [pmid: 15329068].
Cramer J, Ryan J, Chang J, et al. The short-term impact of adjunctive tiagabine on health-related quality of life. Epilepsia. 2001;42:70-5. [pmid: 11520329].
Dam M, Ekberg R, Loyning Y, et al. A double-blind study comparing oxcarbazepine and carbamazepine in patients with newly diagnosed, previously untreated epilepsy. Epilepsy Res. 1989;3:70-6. [pmid: 2645120].
Danner R, Partanen J, Keranen T, et al. Comparison of the effects of carbamazepine and oxcarbazepine on peripheral nerve conduction. Epilepsy Res. 1988;2:272-5. [pmid: 3197697].
Devine ST, Barron J, Behm A. Acute epilepsy exacerbations in patients switched between A-rated anti-epileptic drugs. CMRO. 2010;26:455-63.
Donati F, Gobbi G, Campistol J, et al. The cognitive effects of oxcarbazepine versus carbamazepine or valproate in newly diagnosed children with partial seizures. Seizure. 2007;16:670-9. [pmid: 17574448].
Duh MS, Paradis PE, Latremouille-Viau D, et al. The risks and costs of multiple-generic substitution of topiramate. Neurology. 2009;72:2122-9. [pmid: 19528520].
Fakhoury TA, Hammer AE, Vuong A, et al. Efficacy and tolerability of conversion to monotherapy with lamotrigine compared with valproate and carbamazepine in patients with epilepsy. Epilepsy Behav. 2004;5:532-8. [pmid: 15256191].
Faught E, Sachdeo RC, Remler MP, et al. Felbamate monotherapy for partial-onset seizures: an active-control trial. Neurology. 1993;43:688-92. [pmid: 8469323].
Garnett WR, Gilbert TD, O'Connor P. Patterns of care, outcomes, and direct health plan costs of antiepileptic therapy: a pharmacoeconomic analysis of the available carbamazepine formulations. Clin Ther. 2005;27:1092-103. [pmid: 16154489].
Gillham R, Kane K, Bryant-Comstock L, et al. A double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy with health-related quality of life as an outcome measure. Seizure. 2000;9:375-9. [pmid: 10985991].
Glauser TA, Cnaan A, Shinnar S, et al. Ethosuximide, valproic acid, and lamotrigine in childhood absence epilepsy. N Engl J Med. 2010;362:790-9. [pmid: 20200383].
Glende M, Huller H, Mai I, et al. Comparative bioavailability of two carbamazepine tablets. Int J Clin Pharmacol Ther Toxicol. 1983;21:631-3. [pmid: 6668101].
Gobbi G, Pini A, Bertani G, et al. Prospective study of first-line vigabatrin monotherapy in childhood partial epilepsies. Epilepsy Res. 1999;35:29-37. [pmid: 10232792].
Guerreiro MM, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in children and adolescents with epilepsy. Epilepsy Res. 1997;27:205-13. [pmid: 9237055].
Hartley R, Aleksandrowicz J, Bowmer CJ, et al. Dissolution and relative bioavailability of two carbamazepine preparations for children with epilepsy. J Pharm Pharmacol. 1991;43:117-9. [pmid: 1672895].
Hartley R, Aleksandrowicz J, Ng PC, et al. Breakthrough seizures with generic carbamazepine: a consequence of poorer bioavailability?. Br J Clin Pract. 1990;44:270-3. [pmid: 2206824].
Hodges S, Forsythe WI, Gillies D, et al. Bioavailability and dissolution of three phenytoin preparations for children. Dev Med Child Neurol. 1986;28:708-12. [pmid: 3817309].
Jumao-as A, Bella I, Craig B, et al. Comparison of steady-state blood levels of two carbamazepine formulations. Epilepsia. 1989;30:67-70. [pmid: 2912719].
Kalviainen R, Aikia M, Saukkonen AM, et al. Vigabatrin vs carbamazepine monotherapy in patients with newly diagnosed epilepsy. A randomized, controlled study. Arch Neurol. 1995;52:989-96. [pmid: 7575227].
Kang HC, Eun BL, Wu Lee C, et al. The effects on cognitive function and behavioral problems of topiramate compared to carbamazepine as monotherapy for children with benign rolandic epilepsy. Epilepsia. 2007;48:1716-23. [pmid: 17561952].
Kauko K, Tammisto P. Comparison of two generically equivalent carbamazepine preparations. Ann Clin Res. suppl 11. 1974;6:21-5. [pmid: 4851115].
Kim JM, Kwon S, Seo HE, et al. Long-term effectiveness and tolerability of topiramate in children with epilepsy under the age of 2 years: 4-year follow-up. J Korean Med Sci. 2009;24:1078-82. [pmid: 19949663].
Kim SH, Lee JW, Choi KG, et al. A 6-month longitudinal study of bone mineral density with antiepileptic drug monotherapy. Epilepsy Behav. 2007;10:291-5. [pmid: 17224308].
Kishore K, Jailakhani BL, Sharma JN, et al. Serum phenytoin levels with different brands. Indian J Physiol Pharmacol. 1986;30:171-6. [pmid: 3546122].
Kwan P, Brodie MJ. Effectiveness of first antiepileptic drug. Epilepsia. 2001;42:1255-60. [pmid: 11737159].
Kwan P, Yip FP, Hui AC, et al. Effects of valproate or lamotrigine monotherapy on the reproductive endocrine and insulin-related metabolic profile in Chinese adults with epilepsy: a prospective randomized study. Epilepsy Behav. 2009;14:610-6. [pmid: 19435587].
Labiner D, Paradis PE, Manjunath R, et al. Generic antiepileptic drugs and associated medical resource utilization in the United States. Neurology. 2010;74:1566-74. [pmid: 20393142].
LeLorier J, Duh MS, Paradis PE, et al. Clinical consequences of generic substitution of lamotrigine for patients with epilepsy. Neurology. 2008;70:2179-86. [pmid: 18505997].
Levisohn PM, Holland KD. Topiramate or valproate in patients with juvenile myoclonic epilepsy: a randomized open-label comparison. Epilepsy Behav. 2007;10:547-52. [pmid: 17482520].
Lund L. Clinical significance of generic inequivalence of three different pharmaceutical preparations of phenytoin. Eur J Clin Pharmacol. 1974;7:119-24. [pmid: 4851052].
Ma MS, Ding YX, Ying W, et al. Effectiveness of the first antiepileptic drug in the treatment of pediatric epilepsy. Pediatr Neurol. 2009;41:22-6. [pmid: 19520269].
Marson AG, Appleton R, Baker GA, et al. A randomised controlled trial examining the longer-term outcomes of standard versus new antiepileptic drugs. The SANAD trial. Health Technol Assess. iv. ix. 2007;11:iii-x. 1. 134.
Meador KJ, Loring DW, Hulihan JF, et al. Differential cognitive and behavioral effects of topiramate and valproate. Neurology. 2003;60:1483-8. [pmid: 12743236].
Mikati Bassett NL, Schachter SS. Double-blind randomized study comparing brand name and generic phenytoin monotherapy. Epilepsia. 1990;31:598-9.
Mikati M, Bassett N, Schachter S. Double-blind randomized study comparing brand-name and generic phenytoin monotherapy. Epilepsia. 1992;33:359-65. [pmid: 1547767].
Morrell MJ, Hayes FJ, Sluss PM, et al. Hyperandrogenism, ovulatory dysfunction, and polycystic ovary syndrome with valproate versus lamotrigine. Ann Neurol. 2008;64:200-11. [pmid: 18756476].
Nielsen KA, Dahl M, Tommerup E, et al. Comparative daily profiles with different preparations of lamotrigine: a pilot investigation. Epilepsy Behav. 2008;13:127-30. [pmid: 18406211].
Nieto-Barrera M, Brozmanova M, Capovilla G, et al. A comparison of monotherapy with lamotrigine or carbamazepine in patients with newly diagnosed partial epilepsy. Epilepsy Res. 2001;46:145-55. [pmid: 11463516].
Oles KS, Penry JK, Smith LD, et al. Therapeutic bioequivalency study of brand name versus generic carbamazepine. Neurology. 1992;42:1147-53. [pmid: 1603340].
Pack AM, Morrell MJ, Randall A, et al. Bone health in young women with epilepsy after one year of antiepileptic drug monotherapy. Neurology. 2008;70:1586-93. [pmid: 18443309].
Paradis PE, Latremouille-Viau D, Lefebvre P, et al. Impact of generic substitution of topiramate for patients with epilepsy. Eur J Neurol. 2009;16:140.
Paradis PE, Latremouille-Viau D, Moore Y, et al. Projected economic impact of clinical findings of generic entry of topiramate on G4 European countries. Curr Med Res Opin. 2009;25:1793-805. [pmid: 19505202].
Perry S, Holt P, Benatar M. Levetiracetam versus carbamazepine monotherapy for partial epilepsy in children less than 16 years of age. J Child Neurol. 2008;23:515-9. [pmid: 18182645].
Privitera MD, Brodie MJ, Mattson RH, et al. Topiramate, carbamazepine and valproate monotherapy: double-blind comparison in newly diagnosed epilepsy. Acta Neurol Scand. 2003;107:165-75. [pmid: 12614309].
Ramsay E, Faught E, Krumholz A, et al. Efficacy, tolerability, and safety of rapid initiation of topiramate versus phenytoin in patients with new-onset epilepsy: A randomized double-blind clinical trial. Epilepsia. 2010. July. [Ebup ahead of print].
Rascati KL, Richards KM, Johnsrud MT, et al. Effects of antiepileptic drug substitutions on epileptic events requiring acute care. Pharmacotherapy. 2009;29:769-74. [pmid: 19558250].
Reinikainen KJ, Keranen T, Halonen T, et al. Comparison of oxcarbazepine and carbamazepine: a double-blind study. Epilepsy Res. 1987;1:284-9. [pmid: 3504404].
Reunanen M, Dam M, Yuen AW. A randomised open multicentre comparative trial of lamotrigine and carbamazepine as monotherapy in patients with newly diagnosed or recurrent epilepsy. Epilepsy Res. 1996;23:149-55. [pmid: 8964276].
Reunanen M, Heinonen EH, Nyman L, et al. Comparative bioavailability of carbamazepine from two slow-release preparations. Epilepsy Res. 1992;11:61-6. [pmid: 1563339].
Rowan AJ, Ramsay RE, Collins JF, et al. New onset geriatric epilepsy: a randomized study of gabapentin, lamotrigine, and carbamazepine. Neurology. 2005;64:1868-73. [pmid: 15955935].
Sabers A, Moller A, Dam M, et al. Cognitive function and anticonvulsant therapy: effect of monotherapy in epilepsy. Acta Neurol Scand. 1995;92:19-27. [pmid: 7572056].
Sachdeo R, Kramer LD, Rosenberg A, et al. Felbamate monotherapy: controlled trial in patients with partial onset seizures. Ann Neurol. 1992;32:386-92. [pmid: 1416808].
Sackellares JC, Kwong WJ, Vuong A, et al. Lamotrigine monotherapy improves health-related quality of life in epilepsy: A double-blind comparison with valproate. Epilepsy & Behavior. 2002;3:376-82. [pmid: 12609336].
Saetre E, Perucca E, Isojarvi J, et al. An international multicenter randomized double-blind controlled trial of lamotrigine and sustained-release carbamazepine in the treatment of newly diagnosed epilepsy in the elderly. Epilepsia. 2007;48:1292-302. [pmid: 17561956].
Silpakit O, Amornpichetkoon M, Kaojarern S. Comparative study of bioavailability and clinical efficacy of carbamazepine in epileptic patients. Ann Pharmacother. 1997;31:548-52. [pmid: 9161646].
Sobaniec W, Kulak W, Strzelecka J, et al. A comparative study of vigabatrin vs. carbamazepine in monotherapy of newly diagnosed partial seizures in children. Pharmacol Rep. 2005;57:646-53. [pmid: 16227648].
Soryal I, Richens A. Bioavailability and dissolution of proprietary and generic formulations of phenytoin. J Neurol Neurosurg Psychiatry. 1992;55:688-91. [pmid: 1527539].
Steiner TJ, Dellaportas CI, Findley LJ, et al. Lamotrigine monotherapy in newly diagnosed untreated epilepsy: a double-blind comparison with phenytoin. Epilepsia. 1999;40:601-7. [pmid: 10386529].
Steinhoff BJ, Ueberall MA, Siemes H, et al. The LAM-SAFE Study: lamotrigine versus carbamazepine or valproic acid in newly diagnosed focal and generalised epilepsies in adolescents and adults. Seizure. 2005;14:597-605. [pmid: 16278088].
Stephen LJ, Sills GJ, Leach JP, et al. Sodium valproate versus lamotrigine: a randomised comparison of efficacy, tolerability and effects on circulating androgenic hormones in newly diagnosed epilepsy. Epilepsy Res. 2007;75:122-9. [pmid: 17553671].
Tanganelli P, Regesta G. Vigabatrin vs. carbamazepine monotherapy in newly diagnosed focal epilepsy: a randomized response conditional cross-over study. Epilepsy Res. 1996;25:257-62. [pmid: 8956924].
Vadney VJ, Kraushaar KW. Effects of switching from Depakene to generic valproic acid on individuals with mental retardation. Ment Retard. 1997;35:468-72. [pmid: 9425876].
Wheless JW, Neto W, Wang S, et al. Topiramate, carbamazepine, and valproate monotherapy: double-blind comparison in children with newly diagnosed epilepsy. J Child Neurol. 2004;19:135-41. [pmid: 15072107].
Zachry WM 3rd, Doan QD, Clewell JD, et al. Case-control analysis of ambulance, emergency room, or inpatient hospital events for epilepsy and antiepileptic drug formulation changes. Epilepsia. 2009;50:493-500. [pmid: 18616554].