# Abbreviations

Abbreviation: Definition
“A” Rated generic: Generic drug that is equivalent to the brand name product in safety and effectiveness as determined by FDA
AED: Antiepileptic drug(s)
AOE: Applicability of Evidence
AUC: Area Under the Curve
AV defect: Atrioventricular defect
BCS: Biopharmaceutics Classification System
BMI: Body Mass Index
Ca^2+^: Calcium ion
CI: Confidence Interval
Cmax: Maximum plasma concentration
Cmin: Minimum plasma concentration
Css: Average Steady-state Concentration
CNS: Central Nervous System
CP: Complex Partial Seizures
CR: Controlled Release
CT: X-ray Computed Tomography
CYP: Cytochrome P enzyme
ECG: Electrocardiogram
ECT: Electroconvulsive therapy
EEG: Electroencephalography
EQ-5D: Descriptive Health Related Quality of Life States
ER: Emergency Room
FDA: Food and Drug Administration
GABA: Gamma Amino Butyric Acid
GTCS: Generalized Tonic Clonic Seizures
H: High
HR: Hazard Ratio
I: Insufficient
IBW: Ideal Body Weight
ICS: International Classification of Epileptic Seizures
ILAE: International League Against Epilepsy
IQ: Intelligence Quotient
JME: Juvenile Myoclonic Epilepsy
L: Low
M: Moderate
MRI: Magnetic Resonance Imaging
Na^+^: Sodium ion
NEWQOL: Newly Diagnosed Epilepsy Quality of Life
NMDA: N-methyl D-aspartic acid
NNT: Number Needed to Treat
NRCT: Non Randomized Controlled Trial
OBS: Observational Study
PCOS: Polycystic Ovary Disease
PE: Partial Epilepsy
QOLIE-89: Quality of Life in Epilepsy-89
RCT: Randomized Controlled Trial
RR: Relative Risk
SD: Standard Deviation
SMD: Standardized Mean Difference
SOE: Strength of Evidence
SR: Sustained Release
SANAD: Standard And New Antiepileptic Drugs
SEALS Inventory: Side Effect and Life Satisfaction Inventory
SGOT: Serum Glutamic Oxaloacetic Transaminase
SGPT: Serum Glutamic Pyruvic Transaminase
Tmax: Time to Maximum Concentration
WMD: Weighted Mean Difference