# Glossary

Area Under the Curve: The area under the concentration versus time curve derived when an antiepileptic medication is dosed. Also referred to as the total systemic exposure to the drug over time.
“A” Rated Drug Products: Drug products that are considered to be therapeutically equivalent to other pharmaceutically equivalent products. “A” products are those for which actual or potential bioequivalence problems have been resolved with adequate in vivo and/or in vitro evidence supporting bioequivalence.
Bioequivalent Drug Products: Pharmaceutical equivalent or alternative products that display comparable bioavailability when studied under similar experimental conditions.
Benign Rolandic Epilepsy: An epilepsy syndrome that occurs in childhood and usually resolves by adolescence or early adulthood. It is characterized by simple partial seizures involving the mouth and face or generalized tonic clonic seizures.
Biopharmaceutics Classification System: Classification of antiepileptic medications based on properties and relegated into 4 classes; high solubility/high permeability (Class I, optimal class with lowest risk of absorption variability), low solubility/high permeability (Class II), high solubility/low permeability (Class III) and low solubility/low permeability (Class IV).
Bone Mineral Density (BMD): A measurement of the amount of bone matter per square centimeter, expresses as grams/centimeter^2^ or Z-score.
Cmax: The maximal concentration of antiepileptic medication obtained after dosing.
Confidence Intervals: A range that is likely to include the given value. Usually presented as a percent (%). For example, a value with 95% confidence interval implies that when a measurement is made 100 times, it will fall within the given range 95% of the time.
Correlation Coefficient: A value (which usually ranges from zero to one) that indicates the degree of relationship between two variables. For example, a correlation coefficient of one would indicate a strong relationship.
Css: The concentration of antiepileptic medication obtained at steady state.
DerSimonian and Laird Random-Effects Model: A statistical method based on the assumption that the effects observed in different studies (in a meta-analysis) are truly different.
Health-Related Quality of Life (HRQoL): Assessment of the overall well-being of a patient. Usually in the form of questionnaires that can be tailored to specific disease states such as cystic fibrosis.
Egger's Weighted Regression Statistics: A method of identifying and measuring publication bias.
Epilepsy: A clinical phenomenon in which a person has recurrent seizures due to a chronic underlying process. The main types of seizures include partial (simple partial, complex partial, partial with secondary generalization) and generalized (absence, tonic-clonic, tonic, atonic, myoclonic).
Generalized Epilepsy: A type of epilepsy characterized by seizure activity that occurs in diffuse regions of the brain simultaneously.
I^2^: Measure of degree of variation due to statistical heterogeneity. Usually reported as a percent ranging from 0 to100.
Juvenile Myoclonic Epilepsy: An epilepsy syndrome associated with central nervous system delays or dysfunction from a variety of causes, including developmental abnormalities, perinatal hypoxia/ischemia, trauma, infection, and other acquired lesions.
Lennox-Gastaut Epilepsy Syndrome: An epilepsy syndrome that occurs in children and is defined by the following triad: multiple seizure types (generalized tonic-clonic, atonic, and atypical absence), specific electroencephalographic findings (<3 Hz spike-and-wave discharges), and impaired cognitive function.
Mesial Temporal Lobe Epilepsy Syndrome: An epilepsy syndrome associated with complex partial epilepsy and hippocampal sclerosis.
Meta-analysis: The process of extracting and pooling data from several studies investigating a similar topic to synthesize a final outcome.
Partial Epilepsy: A type of epilepsy characterized by seizure activity in discrete areas of the cerebral cortex.
Publication Bias: The possibility that published studies may not represent all the studies that have been conducted, and therefore, create bias by being left out of a meta-analysis.
Q Statistic: A test to assess the presence of statistical heterogeneity among several studies.
Relative Risks: The ratio of an event occurring in an exposed group to an event occurring in a non-exposed group in a given population. A ratio of one indicates no difference in the risk between the two groups.
Risk Difference: The absolute difference in the event rate between two comparison groups. A risk difference of zero indicates no difference between comparison groups.
Sensitivity Analysis: A “what if” analysis that helps determine the robustness of a study. Helps determine the degree of importance of each variable for a given outcome.
Standard Deviations: A measure of the variability of a data set. For a simple data set with numbers, can be calculated using the following formula:
  σ = ( ( ∑ ( x-x_m_ ) )^2^ / N )^0.5^
  - σ is standard deviation.
  - x_m_ is the average.
  - Σ(x-x_m_) is the sum of x_m_ subtracted from each individual number x.
  - N is the total number of values.
  Note: Other formulas also exist.
Statistical Heterogeneity: Variability in the observed effects among studies in a meta-analysis.
Therapeutic Equivalence: Drug products are considered to be therapeutic equivalents only if they are pharmaceutical equivalents and if they can be expected to have the same clinical effect and safety profile when administered to patients under the conditions specified in the labeling.
Tmax: The time from administration until the Cmax (see Cmax above) is obtained.
Z-Score: The number of standard deviations above or below the mean for the patient's age, sex, and ethnicity.