# Excluded Studies From Full-Text Review

Excluded Studies From Full-Text Review for Innovator Versus Generic Antiepileptic Drug Evaluation

Reference | Reason for Exclusion
Aita JF. Generic vs. branded carbamazepine. Nebraska Medical Journal. 1998; 73(11): 322-3. | Not a report of new discovery in humans
Argumosa A, Herranz JL. The clinical and economic impact of generic drugs in the treatment of epilepsy. Revista de neurologia. 2005; 41(1):45-9. | Not a report of new discovery in humans
Contillo C. Lessons Learned in reno. American Journal of Nursing 2011;111(1): 11. | Not a report of a new discovery in humans
Gagne JJ, Avorn J, Shrank WH, et al. Refilling and switching of antiepileptic drugs and seizure-related events. Clinical pharmacology and therapeutics. 2010; 88 (3): 347-53. | Unable to determine methodology employed in evaluating cases and controls.
Girolineto BM, Alexandre V, Queiroz RH, et al. Interchangeability among therapeutics equivalents of lamotrigine in the treatment of refractory epilepsy patients: risks and benefits. Revista de neurology. 2010; 51 (6): 330-6. | Not in English language
Helmers SL, Paradis PE, Manjunath R, et al. Economic burden associated with the use of generic antiepileptic drugs in the united states. Epilepsy and behavior. 2010; 18 (4): 437-44. | Not evaluating outcomes of interest
Jefferys R. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;65(4):657-8. | Not a report of new discovery in humans
Klingler D, Nitsche V, Schmidbauer H. Diphenylhydantoin intoxication following the exchange of seemingly equal DPH-preparations. Wiener Medizinische Wochenschrift 1981;131(11):295-300. | Not in patients with epilepsy
Moore N, Berdaï D, Bégaud B. Are generic drugs really inferior medicines? Nature. 2010; 88 (3): 302-4. | Not a report of a new discovery in humans
Oles KS, Gal P. Bioequivalency revisited: epitol versus tegretol. Neurology 1993;43(12):2435-6. | Not a report of new discovery in humans
Perron,R. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;64(8):1485-6. | Not a report of new discovery in humans
Rackley,R. J. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;65(4):657-8. | Not a report of new discovery in humans
Sander JW, Ryvlin P, Stefan H, et al. Generic substitution of antiepileptic drugs. Expert reviews in neurotherapeutics. 2010; 10 (12): 1887-98. | Not a report of a new discovery in humans.
Sherry JH, Bechtel T. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;65(4):657-8. | Not a report of new discovery in humans
Simpson GM, Varga E, Reiss M, Cooper TB, Bergner PE, Lee JH. Bioequivalency of generic and brand-named chlorpromazine. Clinical Pharmacology & Therapeutics 1974;15(6):631-41. | Not in patients with epilepsy
Stetz SA. Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;65(4):657-8. | Not a report of new discovery in humans
Lower phenytoin serum levels in persons switched from brand to generic phenytoin. Neurology 2005;64(8):1485-6. | Not a report of new discovery in humans

Excluded Studies From Full-Text Review for Older Versus Newer Antiepileptic Drug Evaluation

Reference | Reason for Exclusion
Aberg,L. E.;Backman,M.;Kirveskari,E.;Santavuori,P. Epilepsy and antiepileptic drug therapy in juvenile neuronal ceroid lipofuscinosis. Epilepsia 2000; 41(10):1296-1302 | Not conducted in an epilepsy population
Andermann,F.;Duh,M. S.;Gosselin,A.;Paradis,P. E. Compulsory generic switching of antiepileptic drugs: high switchback rates to branded compounds compared with other drug classes. Epilepsia 2007;48(3):464-469 | Not reporting outcomes of interest
Antoniuk A, Bruck I, Spessatto A, et al. West syndrome: clinical and electroencephalographic follow up of 70 patients and response to its treatment with adrenocorticotropic hormone, prednisone, vigabatrin, nitrazepam and valproate. Arq Neuropsiquiatr 2000;58(3-A):683-690 | Not conducted in an epilepsy population
Bauer,J.;Buchmuller,L.;Reuber,M.;Burr,W. Which patients become seizure free with antiepileptic drugs? An observational study in 821 patients with epilepsy. Acta Neurol Scand 2008:117:55–59 | Not a comparison of older versus newer antiepileptic drugs
Ben-Menachem E, Brodie M, Perucca E. Efficacy of levetiracetam monotherapy; Randomized double-blind head-to-head comparison with carbamazepine-CR in newly diagnosed epilepsy patients with partial onset or generalized tonic-clonic seizures[abstract]. European Journal of Neurology 2006;13(Suppl. 2):12 | No response from author
Ben-Menachem E, Privitera M, Neto W, et al. Response to topiramate (TPM), carbamazepine (CBZ) or valproate (VPA) by seizure type in newly, diagnosed epilepsy[abstract]. Epilepsia 2005;46(Suppl.6):274 | No response from author
Ben-Menachem E, Privitera M, Wang S, et al. Topiramate, carbamazepine or valproate in newly diagnosed epilepsy: Response by seizure type[abstract]. European Journal of Neurology 2005;12(Suppl. 2):119 | No response from author
Berlowitz,D. R.;Pugh,M. J. Pharmacoepidemiology in community-dwelling elderly taking antiepileptic drugs. International Review of Neurology 2007;81:153-63 | Not a comparison of older versus newer antiepileptic drugs
Boldyreva SR, Ermakov AY. Comparative efficacy of carbamazepine, valproic acid and topiramate in symptomatic and cryptogenic frontal lobe epilepsy in children. Zhurnal Nevrologii i Psikhiatrii Imeni S.S.Korsakova. 2010; 110(6): 58-65. | Not in English language
Boldyreva SR, Ermakov AY. Efficacy of carbamazepine, valproate and topiramate in the treatment of medical temporal epilepsy in children. Zhurnal Nevrologii I Psikhiatrii Imeni S.S. Korsakova. 2010; 110 (4):41-7. | Not in English language
Bondarneko II. Experience in the use of the anticonvulsant pregabalin as an add-on therapy in patients with partial epilepsy with polymorphic seizures. Neuroscience and Behavioral Physiology. 2010; 40 (2): 163-4. | Not a comparison of older versus newer antiepileptic drugs
Brodie M, Ben-Menachem E, Perucca E. Efficacy of levetiracetam monotherapy; Randomised double-blind head-to-head comparison with carbamazepine-CR in newly diagnosed epilepsy patients with partial onset or generalised tonic-clonic seizures[abstract]. European Journal of Neurology 2006;13(Suppl. 2):112 | No response from author
Brodie,M. J.;Yuen,A. W. Lamotrigine substitution study: evidence for synergism with sodium valproate? 105 Study Group. Epilepsy Res 1997;26(3):423-32. | Not a comparison of older versus newer antiepileptic drugs
Bryant-Comstock,L.;Moorat,A. Improvement in quality of life and severity of side effects in patients with epilepsy receiving lamotrigine or valproate [abstract]. Epilepsia 1999;40(Suppl. 7):1999 | No response from the author
Buchanan,N. The use of lamotrigine in juvenile myoclonic epilepsy. Seizure 1996;5:149-151. | Not reporting outcomes of interest
Calloway,M. O.;Blum,D.;Hammer,A. E.;Kustra,R. P. Quality of life in treatment of epilepsy: Lamotrigine versus conventional anti-epileptic drug therapy [abstract]. Epilepsia 2003;44(Suppl. 8):173. | Not a report of a new discovery
Cansu A, Serdaroglu A, Camurdan O, et al. The evaluation of thyroid functions, thyroid antibodies, and thyroid volumes in children with epilepsy during short-term administration of oxcarbazepine and valproate. Epilepsia 2006;47(11):1855–9. | Not reporting outcomes of interest
Cansu A, Serdaroolu A, Yesilkaya E et al. The Effect of Oxcarbazepine and Valproate Therapy on Growth in Children with Epilepsy[abstract]. Epilepsia 2009;50(Suppl. 4):223. | Does not report outcomes of interest
Carius A, Schreiner A, Schauble B. Effectiveness of topiramate in patients with epilepsy transitioning from valproic acid - Results of an open-label, non-interventional trial [abstract]. European Journal of Neurology 2007;14(Suppl. 1):91. | No response from the author
Chung S, Cho E. Age- and dose-related hyponatremia during carbamazepine and oxcarbazepine therapy in children with epilepsy [abstract]. Epilepsia 2006;47(Suppl. 3);172. | Not reporting outcomes of interest
Clemens B, Menes A, Piros P, et al. Quantitative EEG effects of carbamazepine, oxcarbazepine, valproate, lamotrigine, and possible clinical relevance of the findings. Epilepsy Research 2006;70:190-9. | Not reporting outcomes of interest
Contin M, Riva R, Albani F, et al. Effect of felbamate on clobazam and its metabolite kinetics in patients with epilepsy. Therapeutic Drug Monitoring 1999;21:604-8 | Not reporting outcomes of interest
De Romanis F, Sopranzi N. Lamotrigine: monotherapy in refractory epilepsy. Clinica Terapeutica 1997;148:153-8 | Not a comparison of older versus newer antiepileptic drugs
De Romanis F, Sopranzi N. Felbamate: a long-term study in subjects with refractory epilepsy. Clinica Terapeutica 1997;148:83-7 | Not a comparison of older versus newer antiepileptic drugs
DeToledo J, Ramsay R, Lowe M, et al. Increased seizures after discontinuing carbamazepine: results from the gabapentin monotherapy trial. Therapeutic Drug Monitoring 2000;22:753-6 | Not reporting outcomes of interest
Ding YX, Zou LP, Ma MS, et al. Retorspective analysis of the effectiveness of first-line antiepileptic drugs for generalized onset and unclassified epileptic seizures in Chinese children. Childs Nervous System. 2011; 27(2): 279-284. | Not a comparison of older versus newer antiepileptic drugs
Dong X, Leppik I, White J, et al. Hyponatremia from oxcarbazepine and carbamazepine. Neurology 2005;65:1976-8 | Not reporting outcomes of interest
Ehtisham A, Taylor S, Klein M, et al. Cognitive outcomes following seizure prophylaxis for intracranial hemorrhages of different subtypes with levetiracetam versus phenytoin [abstract]. Annals of Neurology 2008;64(Suppl. 12):S30 | Not conducted in an epilepsy population
Ermakov A, Boldyreva S, Litvinovich, The comparative study of effectiveness of lamotrigine and other antiepileptic drugs in cryptogenic and symptomatic focal epilepsy. Zh Neurol Psikhiatr Im SS Korsahova 2007;107(12):94-7 | Not in English language
Eun So-Hee, Eun B, Lee J, et al. The Effects on Cognition and Behavior of Lamotrigine Compared to Carbamazepine as Monotherapy for Children with Partial Epilepsy [abstract]. Epilepsia 2008;49(suppl. 7):88 | No response from the author
Feucht M, Brantner-Inthaler S. Gamma-vinyl-GABA (vigabatrin) in the therapy of Lennox-Gastaut syndrome: an open study. Epilepsia 1994;35(5):993-8 | Not a comparison of older versus newer antiepileptic drugs
Fife D, Blum D, Fisher S. Measuring the effects of antiepileptic medications on balance in older people. Epilepsy Research 2006;70:103-9 | Not reporting outcomes of interest
Filho,G. M. A.;Sousa,P. S.;Garzon,E.;Sakamoto,A. C.;Yacubian,E. M. T. Psychiatric disorders in juvenile myoclonic epilepsy: A study comparing patients treated with valproate and topiramate [abstract]. Epilepsia 2005;46(Suppl. 6);180 | No response from the author
Freidel M, Krause E, Kuhn K, et al. Oxcarbazepine in the treatment of epilepsy. Fortschr Neurol Pshchiat 2007;75:100-6 | Not a comparison of older versus newer antiepileptic drugs
Garg K, Kar M, Singh K. Carbamazepine versus topiramate monotherapy: A prospective comparative study on Indian patients with single small enhancing CT lesions (SSECTLS) and seizures [abstract]. Epilepsia 2003;44 (Suppl. 8):81 | No response from the author
Gates J, McCague K, D'Souza J. Oxcarbazepine is efficacious in patients with partial seizures when switching from carbamazepine phenytoin or valproate [abstract]. Epilepsia 2004;45(Suppl. 7):133 | No response from the author
Gaus V, Coban I, Kretz R, et al. EURAP Germany: Seizure control and dose modifications during pregnancy under treatment with valproate, carbamazepine, and lamotrigine in monotherapy [abstract]. Epilepsia 2006;47(Suppl. S3):125 | Not reporting outcomes of interest
Gaus V, Coban I, Kretz R, et al. Seizure control in the course of pregnancy under treatment with lamotrigine, carbamazepine and valproic acid in monotherapy: Observations from the German EURAP project [abstract]. Epilepsia 2005;46(Suppl. 6):261 | Not reporting outcomes of interest
Gaus V, Cohan I, Dennig D, et al. EURAP Germany: Seizure control and dose modifications during pregnancy under treatment with valproate, carbamazepine and lamotrigine in monotherapy - Update 2007 [abstract]. Epilepsia 2007;48(Suppl. 6):340 | Not reporting outcomes of interest
Gidal E, Tamura T, Hammer A, et al. Blood homocysteine, folate and vitamin B-12 concentrations in patients with epilepsy receiving lamotrigine or sodium valproate for initial monotherapy. Epilepsy Research 2005;64:161-6 | Not reporting outcomes of interest
Gilad R, Sadeh M, Rapoport A, et al. Monotherapy of lamotrigine versus carbamazepine in patients with poststroke seizure. Clin Neuropharmacol 2007;30:189-95 | Not conducted in an epilepsy population
Giorgi L, Gomez G, O'Neill F, et al. The tolerability of lamotrigine in elderly patients with epilepsy. Drugs & Aging 2001;18(8):621-30 | Not a report of a new discovery
Glauser A, Privitera M, Neto W et al. Response of partial-onset or generalized seizures to topiramate, carbamazepine or valproate in newly diagnosed epilepsy [abstract]. Neurology 2005;64(Suppl. 1);A116 | No response from the author
Guido M, de Tommaso M, La Neve A, et al. Event-related potentials in the evaluation of the effect of levetiracetam and carbamazepine on cognitive functions in newly diagnosed epilepsy patients: Preliminary results of a randomised trial [abstract]. Epilepsia 2007;48(Suppl. 8):107 | No response from the author
Guido MT, Goffredo R, Castriota O, et al. Event-related potentials (ERPs) in the evaluation of the effect of levetiracetam and carbamazepine on cognitive functions in adult patients with newly diagnosed epilepsy [abstract]. European Journal of Neurology 2008;15(Suppl. 3):305 | No response from the author
Guo C, Ronen G, Atkinson A. Long-term valproate and lamotrigine treatment may be a marker for reduced growth and bone mass in children with epilepsy. Epilepsia 2001;42(9):1141-7. | Not reporting outcomes of interest
Hallioglu O, Okuyaz C, Mert E, et al. Effects of antiepileptic drug therapy on heart rate variability in children with epilepsy. Epilepsy Research 2008;79:49-54 | Not reporting outcomes of interest
Hamed A, Fida N, Hamed E. States of serum leptin and insulin in children with epilepsy: risk predictors of weight gain. European Journal of Paediatric Neurology 2009;13:261-8 | Not reporting outcomes of interest
Hasan SS, Bahari MB, Babar ZU, et al. Antiepileptic drug utilization and seizure outcome among paediatric patients in a Malaysian public hospital. Singapore Medical Journal. 2010; 51(1): 21-1. | Not reporting outcomes of interest
Hayes F, Caldwell P, Sluss P, et al. Body weight and serum lipid levels in young women with epilepsy treated with valproate versus lamotrigine[abstract]. Epilepsia 2005;46(Suppl. 8):207 | Not reporting outcomes of interest
Heller A, Wright W, LaRoche S, et al. A comparison of levetiracetam and phenytoin as seizure prophylaxis for aneurysmal subarachnoid hemorrhage [abstract]. Epilepsia 2007;48(Suppl. 6):331 | Not conducted in an epilepsy population
Herranz J, Argumosa A, Rejas J, et al. Model-based evaluation of the cost-effectiveness of pregabalin, levetiracetam and generic gabapentin versus standard therapy as an add-on anti-epileptic therapy in patients with refractory epilepsy: A Spanish perspective [abstract]. Epilepsia 2005;46(Suppl. 6):115 | Not a comparison of older versus newer antiepileptic drugs
Hirfanoglu T, Serdaroglu A, Camurdan O, et al. Evaluation of thyroid functions and thyroid volumes in children with epilepsy in long term administration of carbamazepine, oxcarbazepine and valproic acid [abstract]. Epilepsia 2005;46(Suppl. 6):241 | Not reporting outcomes of interest
Hirfanoglu T, Serdaroglu A, Camurdan O, et al. Thyroid function and volume in epileptic children using carbamazepine, oxcarbazepine and valproate. Pediatrics International 2007;49:822-6 | Not reporting outcomes of interest
Hirsch L, Arif H, Nahm E, et al. Cross-sensitivity of skin rashes with antiepileptic drug use. Neurology 2008;71:1527-34 | Not a comparison of older versus newer antiepileptic drugs
Hogan R, Bertrand M, Deaton R, et al. Total percentage body weight changes during add-on therapy with tiagabine, carbamazepine and phenytoin. Epilepsy Research 2000;41:23-8 | Not reporting outcomes of interest
Houtkooper M, Lammertsma A, Meyer J, et al. Oxcarbazepine (GP 47.680): a possible alternative to carbamazepine?. Epilepsia 1987;28(6):693-8 | Not a comparison of older versus newer antiepileptic drugs
Hufnagel A, Limburg S, Evers S, et al. Safety and efficacy of rapidly i.v. titrated levetiracetam versus valproate in patients with partial epilepsy [abstract]. European Journal of Neurology 2009;16(Suppl. 6):473 | No response from the author
Hyson C, Sadler M. Cross sensitivity of skin rashes with antiepileptic drugs. Canadian Journal of Neurological Sciences 1997;24:245-9 | Not reporting outcomes of interest
Inesta I. Carmabazepine in pregnancy: Levetiracetam and lamtrigine are better options. British Medical Journal. 2011; 342: 279. | Not a report of a new discovery in humans
Ishihara L, Webb DJ, Irizarry M, et al. Exploring differential prescribing between anti-epileptic drugs in epilepsy patients with a history of mood disorders. Pharmacoepidemiology and Drug Safety. 2010; 19: 289-295. | Not a comparison of older versus newer antiepileptic drugs
Isojarvi J, Lofgren E, Juntunen K, et al. Effect of epilepsy and antiepileptic drugs on male reproductive health. Neurology 2004;64:247-53 | Not reporting outcomes of interest
Isojarvi J, Turkka J, Pakarinen A, et al. Thyroid function in men taking carbamazepine, oxcarbazepine, or valproate for epilepsy. Epilepsia 2001;42(7):930-4. | Not reporting outcomes of interest
Isojarvi J, Tapanainen J, Rattya J, et al. Changes in Body-Weight, Fasting Serum-Insulin and Testosterone Levels and Ovarian Structure in Women with Epilepsy After Substituting Lamotrigine for Valproate [abstract]. Epilepsia 1995;36:290 | Not reporting outcomes of interest
Isojarvi J, Tapanainen J, Rattya J, et al.Body-Weight, Serum Testosterone Levels, and Ovarian Structure in Women with Epilepsy After Replacement of Valproate with Lamotrigine [abstract]. Epilepsia 1995;36(Suppl. 3):S117 | Not reporting outcomes of interest
Kalviainen R, Aikia M, Mervaala E, et al. Prognosis of Newly-Diagnosed Epilepsy and Effects of Initial Vigabatrin Monotherapy Compared with Carbamazepine Monotherapy [abstract]. Neurology 1994;44(Suppl. 2):A204 | No response from the author
Kalviainen R, Aikia M, Partanen J, et al. Randomized controlled pilot study of vigabatrin versus carbamazepine monotherapy in newly diagnosed patients with epilepsy: an interim report. Journal of Child Neurology 1991;6(Suppl. 2):2S60-9 | Interim report of final analysis Final analysis included in review
Kalviainen R, Halonen T, Pitkanen A, et al.Amino acid levels in the cerebrospinal fluid of newly diagnosed epileptic patients: effect of vigabatrin and carbamazepine monotherapies. Journal of Neurochemistry 1993;60(4):1244-50 | Not reporting outcomes of interest
Kang H, Eun B, Lee C, et al. A multicenter, randomized, open-labeled, clinical study to evaluate the effect on cognitive and behavioral function of topiramate compared with carbamazepine as monotherapy in children with benign rolandic epilepsy [abstract]. Epilepsia 2006;47(Suppl, 4):138 | Meeting abstract for analysis included in review
Kim J, Lee W. Metabolic and hormonal disturbances in women with epilepsy on antiepileptic drug monotherapy. Epilepsia 2007;48(7):1366-70 | Not reporting outcomes of interest
Korabathina K, Benbadis S. Levetiracetam is as effective as carbamazepine in newly diagnosed epilepsy. Expert Review of Neurotherapeutics 2007;7(6):599-601 | Not a report of a new discovery in humans
Kurul S, Dirik E, Iscan A. Serum carnitine levels during oxcarbazepine and carbamazepine monotherapies in children with epilepsy. Journal of Child Neurology 2003;18:552-4 | Not reporting outcomes of interest
Kustra R, Morrell M, Hayes F, et al. The incidence of components of polycystic ovary syndrome is higher in young women with epilepsy treated with valproate versus lamotrigine [abstract]. Epilepsia 2006;47(Suppl. S3):124 | Not reporting outcomes of interest
Kuzmanovski I, Nikodijevic-Kedeva D, Petrovska D, et al. Tegretol versus lamotrigine in patients with partial refractory epilepsy: a 6 month clinical study [abstract]. Epilepsia 2004;45(Suppl. 3):134 | No response from the author
Kwon S, Lee S, Hyun M, et al. The potential for QT prolongation by antiepileptic drugs in children. Pediatric Neurology 2004;30(2):99-101 | Not reporting outcomes of interest
Labar R. Antiepileptic drug use during the first 12 months of vagus nerve stimulation therapy: a registry study. Neurology 2002;59(6) | Not a comparison of older versus newer antiepileptic drugs
Leach J, Brodie M, Sills G, et al. Randomised comparison of lamotrigine and valproate in newly diagnosed epilepsy - Efficacy, tolerability, and endocrine effects[abstract]. Epilepsia 2006;47(Suppl. 4):164 | No response from the author
Lee SA, Heo K, Kim WJ, et al. Clinical feasibility of immedicate overnight switching from slow-release carbamazepine to oxcarbazepine in Korean patients with refractory partial epilepsy. Seizure. 2010; 19(6): 356-8. | Not a comparison of older versus newer antiepileptic drugs
Legros B, Bazil C. Effects of antiepileptic drugs on sleep architecture: a pilot study. Sleep Medicine 2003;4:51–5 | Not reporting outcomes of interest
Levisohn P, Holland K, Hulihan J, et al. Topiramate or valproate in juvenile myoclonic epilepsy[abstract]. Child Neurology Society 2004;56:S117 | No response from the author Duplicate of full text article included in evaluation
Levisohn P, Holland K, Hulihan J, et al. Topiramate versus valproate in patients with juvenile myoclonic epilepsy [abstract]. Epilepsia 2003;44,(Suppl. 9):267 | No response from the author Duplicate of full text article included in evaluation
Lim D, Tarapore P, Chang E, et al. Safety and feasibility of switching from phenytoin to levetiracetam monotherapy for glioma-related seizure control following craniotomy: a randomized phase II pilot study. Journal of Neurooncology 2009;93:349–354 | Not conducted in an epilepsy population
Lim D, Tarapore P, Chang E, et al. Comparison of levetiracetam monotherapy with continued phenytoin therapy after supratentorial craniotomies in patients with a history of tumor-related seizures: A phase II, pilot study[abstract]. Epilepsia 2007;48(S6):343 | Not conducted in an epilepsy population
Lim K, Kim H. Low-dose topiramate compared with carbamazepine in treating benign rolandic epilepsy [abstract]. Epilepsia 2004;45(Suppl. 7):322 | Not conducted in an epilepsy population
Lofgren E, Tapanainen J, Koivunen R, et al. Effects of carbamazepine and oxcarbazepine on reproductive endocrine function in women with epilepsy [abstract]. Epilepsia 2005;46(Suppl. 8):87 | Not reporting outcomes of interest
Lofgren E, Tapanainen J, Koivunen R, et al. Effects of carbamazepine and oxcarbazepine on the reproductive endocrine function in women with epilepsy. Epilepsia 2006;47(9):1441-6 | Not reporting outcomes of interest
Loring D, Kamin M, Karim R. Topiramate and valproate added to carbamazepine: Effect on cognitive function in adults with epilepsy [abstract]. Neurology 2001;56(Suppl 3):A334. | No response from the author
Luef G, Rauchenzauner M, Waldmann M, et al. Non-alcoholic fatty liver disease (NAFLD), insulin resistance and lipid profile in antiepileptic drug treatment. Epilepsy Research 2009:86:42-7 | Not reporting outcomes of interest
Lukic S, Spasic M. Treatment of newly diagnosed epilepsy with valproate and lamotrigine [abstract]. European Journal of Neurology 2004;11(Suppl. 2):227 | No response from author
Lukic S, Spasic M, Lukic N. Comparison of valproate and lamotrigine for treatment of newly diagnosed epilepsy - interim report [abstract]. European Journal of Neurology 2005;12(Suppl. 2):237 | No response from author
Majkowska-Zwolinska B, Jedrzejczak J, Zwolinski P, et al. The Effectiveness of Oxcarbazepine After Switch from Carbamazepine in the Treatment of Partial Epilepsy Evaluated in Daily Routine Medical Practice in Poland. Results of a National, Observational ‘E-Pill Study’ [abstract]. Epilepsia 2009;50(Suppl. 4):198-9 | No response from author
Martsenkovsky I, Bikshaeva J, Martsenkovska I, et al. Efficacy of monotherapy and polytherapy by topiramate and valproate in childhood epileptic encephalopathy (Lennox-Gastaut syndrome) [abstract]. Epilepsia 2006;47(Suppl. 3):141 | No response from author
Martyniuk V, Kharytonov V, Yarmolyuk T. Efficacy and Safety of Topiramate Monotherapy Comparing with Carbamazepine and Lamotrigine in Treatment of Recently Diagnosed Epilepsies with Partial Seizures [abstract]. Epilepsia 2009;50(Suppl. 4):230 | No response from author
Mazurkiewicz-Beldzinska M, Matheisel A, Szmuda,M. Long Term Retention Rates of Valproate Versus Lamotrigine in Idiopathic Generalized Epilepsies [abstract]. Epilepsia 2009;50(Suppl. 10):102 | Not reporting outcomes of interest
Mazurkiewicz-Beldzinska M, Matheisel A, Szmuda M. Long term efficacy of valproate versus lamotrigine in treatment of idiopathic generalized epilepsies [abstract]. European Journal of Neurology 2009;16(Suppl. 3):140 | Not reporting outcomes of interest
Mazurkiewicz-Beldzinska M, Marta S, Matheisel A. Long-term efficacy of valpraote versus lamotrigine in treatment of idiopathic generalized epilepsies in children and adolescents. Seizure 2010;19:195-7 | Not reporting outcomes of interest
McCrindle S, Parker P, Stephen L, et al. Randomised comparison of sodium valproate and lamotrigine in newly diagnosed epilepsy [abstract]. Epilepsia 2003;44(Suppl. 8):133 | No response from author
McVearry K, Gaillard W, VanMeter J, et al. A prospective study of cognitive fluency and originality in children exposed in utero to carbamazepine, lamotrigine, or valproate monotherapy[abstract]. Epilepsy & Behavior 2009;16:609-16 | Not reporting outcomes of interest
Meador KJ, Gevins A, Leese PT, et al. Neurocognitive effects of brivaracetam, levetiracetam, and lorazepam. Epilepsia. 2011; 52(2): 264-272. | Not a comparison of older versus newer antiepileptic drugs
Meador K, Baker G, Finnell R, et al. In utero antiepileptic drug exposure: fetal death and malformations. Neurology 2006;67:407–12 | Not reporting outcomes of interest
Meischenguiser R, D'Giano C, Ferraro S. Oxcarbazepine in pregnancy: clinical experience in Argentina. Epilepsy & Behavior 2004;5:163-7 | Not reporting outcomes of interest
Mervaala E, Partanen J, Nousianinen U, et al. Electrophysiologic effects of gamma-vinyl GABA and carbamazepine. Epilepsia 1989;30(2):189-93 | Not reporting outcomes of interest
Mikkonen K, Knip M, Pakarinen A, et al. Growth and lipid metabolism in girls and young women with epilepsy during pubertal maturation. Epilepsia 2005;46(7):1114–1120 | Not reporting outcomes of interest
Mikkonen K, Tapanainen P, Pakarinen A, et al. Serum androgen levels and testicular structure during pubertal maturation in male subjects with epilepsy. Epilepsia 2004;45(7):769-76 | Not reporting outcomes of interest
Mikkonen K, Vainionpaa L, Pakarinen A, et al. Long-term reproductive endocrine health in young women with epilepsy during puberty. Neurology 2004;62:445-50 | Not reporting outcomes of interest
Mintzer S, Boppana P, Toguri J, et al. Vitamin D levels and bone turnover in epilepsy patients taking carbamazepine or oxcarbazepine. Epilepsia 2006;47(3):510-15 | Not reporting outcomes of interest
Mintzer S, Toguri J, Boppana P, et al. Vitamin D levels and bone turnover in epilepsy patients taking oxcarbazepine or carbamazepine. Epilepsia 2005;46(Suppl. 8):214 | Not reporting outcomes of interest
Mirza W, Biton V, Barrett P, et al. Weight gain associated with valproate monotherapy in patients with epilepsy: An interim analysis of a randomized, double-blinded comparative clinical trial with lamotrigine[abstract]. Epilepsia 1999;40(Suppl. 2):282 | No response from author
Mockenhaupt M, Messenheimer J, Tennis P, et al. Risk of Stevens-Johnson syndrome and toxic epidermal necrolysis in new users of antiepileptics. Neurology 2004;65:1134-8 | Not reporting outcomes of interest
Mohanraj R, Brodie M. Outcomes of newly diagnosed idiopathic generalized epilepsy syndromes in a non-pediatric setting. Acta Neurol Scand 2007;115:204-8 | Not reporting outcomes of interest
Mohanraj R, Brodie M. Pharmacological outcomes in newly diagnosed epilepsy. Epilepsy & Behavior 2005;6:382-7 | Not reporting outcomes of interest
Moreno M, Giagante B, Saidon P, et al. Visual defects associated with vigabatrin: a study of epileptic argentine patients. Canadian Journal of Neurological Sciences 2005;32:459-64 | Not reporting outcomes of interest
Morrell M, Hayes F, Sluss P, et al. Reproductive endocrine function in women with epilepsy treated with lamotrigine versus valproate [abstract]. Neurology 2006;66(5):A72 | Not reporting outcomes of interest
Morrell M, Hayes F, Sluss P et al. Higher incidence of components of polycystic ovary syndrome in young women with epilepsy treated with valproate versus lamotrigine[abstract]. Epilepsia, 2005;46(Suppl. 8):88 | Not reporting outcomes of interest
Morrell M, Isojarvi J, Taylor A, et al. Higher androgens and weight gain with valproate compared with lamotrigine for epilepsy. Epilepsy Research 2003;54:189-99 | Not reporting outcomes of interest
Morrell M, Isojarvi J, Gomez G, et al. Cross-sectional study comparing weight gain and androgen levels in women with epilepsy taking lamotrigine compared to valproate monotherapy[abstract]. Epilepsia 2009;50(Suppl. 4):192 | No response from author
Nicolson A, Appleton R, Chadwick D, et al. The relationship between treatment with valproate, lamotrigine, and topiramate and the prognosis of the idiopathic generalised epilepsies. Journal of Neurology Neurosurgery and Psychiatry 2004;75:75-9 | Not reporting outcomes of interest
Nikodijevie-Kedeva D, Nikolovski G, Petrovska-Cvetkovska D, et al. Quality of life in treatment of epilepsy: Topiramate compared to conventional AEDs-carbamazepine and valproic acid [abstract]. Epilepsia 2005;46(Suppl.6):114 | No response from author
Nikoloski G. Etotal Antioxidant Status (Tas) in Patients with Epilepsy on Monotherapy with Carbamazepine (Cbz) and Lamotrigine (Ltg)[abstract]. Epilepsia 2009;50(Suppl. 4):192 | Not reporting outcomes of interest
Nolt D, Mott J, Lopez W. Assessment of anticonvulsant effectiveness and safety in patients with Angelman's syndrome using an Internet questionnaire. American Journal of Health-Systems Pharmacists 2003;60:2583-7 | Not reporting outcomes of interest
Nousiainen I, Kalviainen R, Mantyjarvi M. Contrast and glare sensitivity in epilepsy patients treated with vigabatrin or carbamazepine monotherapy compared with healthy volunteers. British Journal of Opthamology 2000;84:622-5 | Not reporting outcomes of interest
Nousiainen I, Kalviainen R, Mantyjarvi M. Color vision in epilepsy patients treated with vigabatrin or carbamazepine monotherapy. Opthamology 2000;107:884-8 | Not reporting outcomes of interest
Pace A, Bove L, Innocenti P, et al. Epilepsy and gliomas: incidence and treatment in 119 patients. Journal of Experimental Clinical Cancer Research 1998;17(4):479-82 | Not reporting outcomes of interest
Paciello N, Marchi P, Chiummiento M, et al. Levetiracetam vs carbamazepine in epileptic elderly patients[abstract]. Epilepsia 2006;47(S4):168 | No response from author
Pack A, Morrell M, Marcus R, et al. Bone mass and turnover in women with epilepsy on antiepileptic drug monotherapy. Annals of Neurology 2005;57:252-7 | Interim report for trial included in evaluation
Papacostas S. Oxcarbazepine versus carbamazepine treatment and induction of serum lipid abnormalities. Journal of Child Neurology 2000;15:138-40 | Not reporting outcomes of interest
Perry M, Holt P, Olson L, et al. Comparison of levetiracetam and carbamazepine monotherapy for partial seizures in children less than 16 years of age: A retrospective review [abstract]. Annals of Neurology 2007;62(Suppl 11):S138 | No response from author
Perry M, Holt P, Olson L, et al. Comparison of levetiracetam and carbamazepine as initial monotherapy for newly diagnosed epilepsy in children < 16 years old: A retrospective review[abstract]. Epilepsia 2007;48:351 | No response from author
Petroff O, Hyder F, Rothman D, et al. Homocarnosine and seizure control in juvenile myoclonic epilepsy and complex partial seizures. Neurology 2001;56:709-15 | Not evaluating endpoints of interest
Petroff O, Hyder F, Rothman D, et al. Brain GABA levels are below normal in epilepsy patients treated with valproate and lamotrigine[abstract]. Annals of Neurology 1999;46(3):455 | Not evaluating endpoints of interest
Petrovska-Cvetkovska D, Nikodijevic D, Dzonov I. Quality of Life in Treatment of Elderly Patients with Epilepsy: Lamotrigine and Topiramate Versus Conventional Aeds-Carbamazepine and Valproic Acid [abstract]. Epilepsia 2009;50(Suppl. 4):163 | No response from author
Piattella L, Zamponi N, Cardinali C. Vigabatrin Versus Carbamazepine in Newly-Diagnosed Partial Epilepsy in Childhood [abstract]. Epilepsia 1995;36(Suppl. 3):S103 | No response from author
Pienimaki P, Lampela E, Hakkola J, et al. Pharmacokinetics of oxcarbazepine and carbamazepine in human placenta. Epilepsia 1997;38(3):309-16 | No evaluating endpoints of interest
Pisani F, Oteri G, Russo M, et al. The efficacy of valproate-lamotrigine comedication in refractory complex partial seizures: evidence for a pharmacodynamic interaction. Epilepsia 1999;40(8):1141-6 | No evaluating endpoints of interest
Pohlmann-Eden B, Van Paesschen W, Hallstrom Y, et al. The Komet Study: an Open-Label, Randomized, Parallel-Group Trial Comparing the Efficacy and Safety of Levetiracetam with Sodium Valproate and Carbamazepine as Monotherapy in Subjects with Newly Diagnosed Epilepsy [abstract]. Epilepsia, 2008;49(suppl. 7):448-9 | No response from author
Prasad A, Kuzniecky R, Knowlton R, et al. Evolving antiepileptic drug treatment in juvenile myoclonic epilepsy. Archives of Neurology 2003;60:1100-5 | No evaluating endpoints of interest
Privitera M, Brodie M, Neto W, et al. Topiramate, carbamazepine, and valproate in the spectrum of newly diagnosed epilepsy [abstract]. Neurology 2001;56(8):332 | Duplicate of full text included in the analysis
Pylvanen V, Knip M, Pakarinen J, et al. Fasting serum insulin and lipid levels in men with epilepsy. Neurology 2003;60:571-4 | No evaluating endpoints of interest
Ramsay E, Faught E, Krumholz A, et al. Efficacy, Tolerability and Safety of Initial Monotherapy Topiramate Vs Phenytoin in Patients with New-Onset Epilepsy [abstract]. Epilepsia 2008;49(Suppl. 7):115-6 | No response from author
Ramsay E, Pryor F, Collins J. Comparative efficacy of carbamazepine, gabapentin, and lamotrigine in new onset geriatric epilepsy stratified by decade[abstract]. Neurology 2007;68(12):A97 | No response from author
Ramsay T, Bainbridge J, Fredricks T, et al. Results of a randomized double-blind comparison of levetiracetam & carbamazepine in new onset seizures in a geriatric population [abstract]. Epilepsia 2007;48(Suppl. 6):36-7 | No response from author
Rattya J, Turkka J, Pakarinen A, et al. Reproductive effects of valproate, carbamazepine, and oxcarbazepine in men with epilepsy. Neurology 2001;56:31-6 | No evaluating endpoints of interest
Rattya J, Turkka J, Paskarinen A, et al. Reproductive endocrine effects of valproate, carbamazepine and oxcarbazepine in men with epilepsy[abstract]. Epilepsia 1999;40(Suppl. 2):194-5 | No evaluating endpoints of interest
Rattya J, Vainionpaa L, Knip M, et al. The effects of valproate, carbamazepine, and oxcarbazepine on growth and sexual maturation in girls with epilepsy. Pediatrics 1999;130(3):588-93 | No evaluating endpoints of interest
Resendiz-Aparicio J, Rodriguez-Rodriguez E, Contreras-Bernal J, et al. A randomised open trial comparing monotherapy with topiramate versus carbamazepine in the treatment of paediatric patients with recently diagnosed epilepsy. Revista de Neurology 2004;39(3):201-4 | Not in English language
Rimmer E, Milligan N, Richens A. A comparison of the acute effect of single doses of vigabatrin and sodium valproate on photosensitivity in epileptic patients. Epilepsy Research 1987;1(6):339-46 | No evaluating endpoints of interest
Ronga B, Andreone V, Pagliuca M. Lamotrigine versus valproate as monotherapy in adult patients with idiopathic generalized epilepsy[abstract]. Epilepsia 1999;40(Suppl. 2):284 | No response from author
Rudakova G, Morozova O, Kotov A. Impact of the current antiepileptic drugs on quality of life of epileptic patients. Zhurnal Nevrologii i Psikhiatrii Imeni S.S.Korsakova 2008;3:36-40 | Not in English language
Rufo Campos M, Carreno,M. Utilization of carbamazepine and oxcarbazepine in pediatric patients with partial epilepsy in Spain. An observational study. Neurologia 2009;24(1):30-9 | Not a comparison of older versus newer antiepileptic drugs
Sabers A, Dam M, A-Rogvi-Hansen B et al. Epilepsy and pregnancy: lamotrigine as main drug used. Acta Neurologica Scandinavica 2004;109:9-13 | No evaluating endpoints of interest
Sackellares C, Vuong A, Hammer A. Lamotrigine monotherapy improves mood in adolescents with epilepsy: A randomized, double-blind comparison with valproate [abstract]. Epilepsia 2004;45(Suppl. 70):356 | No response from author
Saetre E, Abdelnoor M, Amlie J, et al. Cardiac function and antiepileptic drug treatment in the elderly: a comparison between lamotrigine and sustained-release carbamazepine. Epilepsia 2009;50(8):1841-9 | No evaluating endpoints of interest
Saetre E, Ansteensen G, Perucca E et al. Randomised double-blind trial of lamotrigine versus sustained-release carbamazepine in newly diagnosed elderly epilepsy patients: A preliminary analysis [abstract]. Epilepsia 2005;46(Suppl. 6):278 | No response from author
Saetre E, Ansteensen G, Perucca E, et al. Safety of Antiepileptic drug treatment in old age. experiences from the European multi-center double-blind comparative study of lamotrigine and slow-release carbamazepine in newly diagnosed elderly epilepsy patients (LAM 40089 trial) [abstract]. Neurology 2005;64(Suppl. 10):A190 | No response from author
Saetre E, Perucca E, Gjerstad L, et al. An international multi-centre double-blind randomised comparative trial of lamotrigine and slow release carbamazepine in elderly patients with newly diagnosed epilepsy: a preliminary analysis [abstract]. Epilepsia 2004;45(Suppl. 3):135 | No response from author
Saetre E, Perucca E, Isojarvi J, et al. An international multicenter double-blind double-dummy randomised trial comparing lamotrigine and slow-release carbamazepine for treating newly diagnosed epilepsy in the elderly[abstract]. Epilepsia 2006;47(S3):1 | No response from author
Saetre E, Perucca E, Isojarvi J, et al. An international multicenter double-blind randomised comparative trial of lamotrigine and slow release carbamazepine in elderly patients with newly diagnosed epilepsy [abstract]. Epilepsia, 2005;46(Suppl. 8):216 | No response from author
Schmidt T, Schmitz B, Jokiel B, et al. Constriction of the visual field in epilepsy patients taking vigabatrin and other antiepileptic drugs: A longitudinal study[abstract]. Epilepsia 1999;40(Suppl. 2):256 | No evaluating endpoints of interest
Schumacher T, Beck H, Steinhauser C, et al. Effects of phenytoin, carbamazepine, and gabapentin on calcium channels in hippocampal granule cells from patients with temporal lobe epilepsy. Epilepsia 1998;39(4):355-63 | No evaluating endpoints of interest
Selai C, Trimble M. Adjunctive therapy in epilepsy with new antiepileptic drugs: is it of any value?. Seizure 1998;7:417-8 | No evaluating endpoints of interest
Serdaroglu A, Cansu A, Camurdan O, et al. Short-term evaluation of thyroid functions and volumes in children with epilepsy treated with oxcarbazepine and valproic acid [abstract]. Epilepsia 2005;46(Suppl.6):282 | No evaluating endpoints of interest
Shakespeare A, Simeon G. Economic analysis of epilepsy treatment: a cost minimization analysis comparing carbamazepine and lamotrigine in the UK. Seizure 1998;7:119-25 | No evaluating endpoints of interest
Sillanpaa M, Pihlaja T. Oxcarbazepine (GP 47 680) in the treatment of intractable seizures. Acta Paediatrica Hungarica 1989-99;29(3-4):359-64 | No evaluating endpoints of interest
Sills G, Stephen L, Butler E, et al. A randomised open-label comparison of the efficacy, tolerability, and hormonal effects of sodium valproate and lamotrigine monotherapy in newly-diagnosed epilepsy [abstract]. Epilepsia 2006:47(S3):1 | No response from author
Smith D, Marson A, Smith C, et al. Valproate versus lamotrigine and topiramate for epilepsy: Results from arm B of the sanad trial [abstract]. Epilepsia 2006;47(Suppl. 4):247 | Duplicate of full text included in the evaluation
Sokolova L, Kalinin V, Zheleznova E, et al. Comparison of efficacy of trileptal (oxcarbazepine) and carbamazepine in the treatment of temporal epilepsy. Zhurnal Nevrologii i Psikhiatrii Imeni S.S.Korsakova 2008;(Suppl. 2):63-7 | Not in English language
Sorokina N, Selitsky G. Cognitive effects of topiramate and depakine for frontal lobe epilepsy[abstract]. Epilepsia 2005;6(Suppl.6):311 | No response from author
Specchio L, Goffredo R, Castriota O, et al. Event-Related Potentials (Erps) in the Evaluation of the Effect of Levetiracetam and Carbamazepine on Cognitive Functions in Adult Newly Diagnosed Epileptic Patients. Preliminary Results of a Randomized Open Trial[abstract]. Epilepsia 2009;50(Suppl. 4):98 | No response from author
Steinhoff B, Freudenthaler N, Paulus W. The influence of established and new antiepileptic drugs on visual perception. II. A controlled study in patients with epilepsy under long-term antiepileptic medication. Epilepsy Research 1997;29:49–58 | No evaluating endpoints of interest
Steinhoff B, Ueberall M, Siemes H, et al. The lam-safe study: lamotrigine versus carbamazepine and valproic acid in newly diagnosed focal and generalised epilepsies in adolescents and adults [abstract]. Epilepsia 2004;45(Suppl. 3):68 | No response from author
Stephen L, Kwan P, Shapiro D, et al. Hormone profiles in young adults with epilepsy treated with sodium valproate or lamotrigine monotherapy. Epilepsia 2001;42(8):1002-6 | No evaluating endpoints of interest
Sturm Y, Miller M. Long-term oxcarbazepine therapy in children is at least as effective as and better tolerated than phenytoin[abstract]. Epilepsia 2003;44(Suppl. 9):272 | No response from author
Svalheim S, Tauboll E, Luef G, et al. Differential effects of levetiracetam, carbamazepine, and lamotrigine on reproductive endocrine function in adults. Epilepsy & Behavior 2009;16:281-7 | No evaluating endpoints of interest
Svalheim S, Tauboll E, Rauchenzauner M, et al. Levetiracetam, Lamotrigine and Carbamazepine Differentially Influence Sex Steroid Hormones in Patients with Epilepsy [abstract]. Epilepsia 2008;49(suppl. 7):458 | No evaluating endpoints of interest
Tanabe T, Awaya Y, Matsuishi T, et al. Management of and prophylaxis against status epilepticus in children with severe myoclonic epilepsy in infancy (SMEI; Dravet syndrome)--a nationwide questionnaire survey in Japan. Brain & Development 2008;30:629-35 | No evaluating endpoints of interest
Tanganelli P, Regesta G. Vigabatrin Versus Carbamazepine in Newly-Diagnosed Epileptic Patients - a Randomized-Response Conditional Cross-Over Study[abstract]. Epilepsia 1999;36(Suppl. 3):S104 | No response from author
Tonekaboni SH, Ghazavi, Karimzadeh P, et al. Efficacy of levetiracetam in children with refractory epilepsy as an add-on trial. Epilepsy Research. 2010; 90(3): 273-7. | Not a comparison of older versus newer antiepileptic drugs
Trinka E, VanPaesschen W, Hallstrom Y, et al. The Komet Study: an Open-Label, Randomized, Parallel-Group Trial Comparing the Efficacy and Safety of Levetiracetam with Sodium Valproate and Carbamazepine as Monotherapy in Subjects with Newly Diagnosed Epilepsy[abstract]. Epilepsia 2009;50(Suppl. 4):45 | No response from author
Tripathi M, Vibha D, Choudhary N, et al. Management of refractory status epilepticus at a tertiary care center in a developing country. Seizure. 2010; 19(2): 109-11. | Not a comparison of older versus newer antiepileptic drugs
Trudeau V, Dimond K, Smith F et al. Gabapentin (Gbp Neurontin(r)) Monotherapy Compared with Carbamazepine (Cbz) Monotherapy and Combination Gbp Plus Cbz (Gbp/cbz) Therapy in Patients with Medically Refractory Partial Seizures - a 3-Way Cross-Over Trial (94536)[abstract]. Epilepsia 1995;36(Suppl. 4):68 | No response from author
Tutor-Crespo M, Hermida J, Tutor J. Relation of blood platelet count during carbamazepine and oxcarbazepine treatment with daily dose, and serum concentrations of carbamazepine, carbamazepine-10, 11-epoxide, and 10-hydroxycarbazepine. Biomedical Papers of the Medical Faculty of Palacky University in Olomouc, Czech Republic 2007;151(1):91-4 | No evaluating endpoints of interest
Vainionpaa L, Mikkonen,K.;Rattya,J, et al. Thyroid function in girls with epilepsy with carbamazepine, oxcarbazepine, or valproate monotherapy and after withdrawal of medication. Epilepsia 2004;45(3):197–203 | No evaluating endpoints of interest
Vajda FJ, Graham JE, Hitchcock AA, et al. Is lamotrigine a significant human teratogen? Observations from the Australian pregnancy register. Seizure 2010; 19(9): 558-61. | No evaluating endpoints of interes
Vajda FJ, Hollingworth S, Graham J, et al. Changing patterns of antiepileptic drug use in pregnant Australian women. 2010; 121(2): 89-93. | No evaluating endpoints of interes
Vajda F, Hitchcock A, Graham J, et al. Foetal malformations and seizure control: 52 months data of the Australian Pregnancy Registry. European Journal of Neurology 2006;13:645-54 | No evaluating endpoints of interest
Vajda F, O'Brien T, Hitchcock A, et al. The Australian registry of anti-epileptic drugs in pregnancy: experience after 30 months. Journal of Clinical Neuroscience 2003;10(5):543-9 | No evaluating endpoints of interest
Van Paesschen W, Duncan J, Connelly A. A comparison of the neuropathological effects of vigabatrin and carbamazepine in patients with newly diagnosed localization-related epilepsy using MR-based cerebral T2 relaxation time measurements. Epilepsy Research 1998;29:155-60 | No evaluating endpoints of interest
Vasquez B, Sachdeo R, Chang G, et al. Tiagabine or phenytoin as first add-on therapy for complex partial seizures[abstract]. Neurology 1998;50:A199 | No response from author
Vestergaard P, Rejnmark L, Mosekilde L. Fracture risk associated with use of antiepileptic drugs. Epilepsia 2004;45(11):1330-7 | Not evaluating endpoints of interest
Viteri C, Codina M, Cobaleda S, et al. Quality of life and treatment satisfaction in Spanish epilepsy patients on monotherapy with lamotrigine or valproic acid. Seizure 2010; 19(7): 432-8. | Not evaluating endpoints of interest
Viteri C, Codina M, Cobaleda S, et al. Validacion de la version espanola del cuestionario de calidad de vida en epilepsia QOLIE-10. Neurologia 2008;23(3):157-67 | Not in English language
Wheless J, Neto W, Twyman R. Topiramate, carbamazepine, and valproate as first-line monotherapy in children/adolescents with newly diagnosed epilepsy[abstract]. Annals of Neurology 2003;54:S135-6 | No response from author
Wheless J, Neto W, Wang S. Topiramate, carbamazepine, and valproate in children with newly diagnosed epilepsy: A unique trial design[abstract]. Neurology 2001;56(8):A234-5 | No response from author
Wilensky A, Friel P, Ojemann L, et al. Zonisamide in epilepsy: a pilot study. Epilepsia 1985;26(3):212-20 | No evaluating endpoints of interest
Williamson P, Kolamunnage-Dona R, Philipson P, et al. Joint modelling of longitudinal and competing risks data. Statististics in Medicine 2008; 27:6426-38 | No evaluating endpoints of interest
Yu L, Huang Y, Sun H, et al. Effects of topiramate and carbamazepine on thyroid hormone level in adults with epilepsy. Neural Regeneration Research 2006;1(8):706-9 | No evaluating endpoints of interest
Yu P, Zhu G, Xu Y, et al. Cognitive Function and Quality of Life Effect of Valproate, Carbamazepine, and Lamotrigine in Patients with Newly Diagnosed Epilepsy After 2-Year Follow-Up [abstract]. Epilepsia 2009;50(Suppl. 10):139 | No response from author
Zamponi N, Cardinali C. Open comparative long-term study of vigabatrin vs carbamazepine in newly diagnosed partial seizures in children. Archives of Neurology 1999;56:605-7 | No evaluating endpoints of interest
Zarubova J, Hill M. The Effect of Lamotrigine, Carbamazepine and Valproate on the Levels of Free and Conjugated Steroids in the Serum of Premenopausal Women with Epilepsy[abstract]. Epilepsia 2009;50(Suppl. 4):84 | No response from author
Zeber JE, Copeland LA, Pugh MJV. Variation in Antiepileptic drug adherence among older patients with new-onset epilepsy. Neurology 2010; 44(12): 1896-1904. | No evaluating endpoints of interest
Zelnik,N.;Isler,N.;Goez,H, et al. Vigabatrin, lamotrigine, topiramate and serum carnitine levels. Pediatric Neurology 2008;39:18-21 | No evaluating endpoints of interest