# Data Extraction Forms

Data Extraction Forms for Innovator versus Generic Antiepileptic Drug Evaluation

Data Extraction Forms for Older versus Newer Antiepileptic Drug Evaluation