# Search Strategies

Search Strategy for Innovator versus Generic Antiepileptic Drug Evaluation for MEDLINE, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews (each in OVID starting in 1950), Web of Science (limited to meeting abstracts only)

1. generic.mp.
2. innovator.mp.
3. nonproprietary.mp.
4. drugs, generic/
5. therapeutic equivalency/
6. (brand adj name).mp.
7. 1 or 2 or 3 or 4 or 5 or 6
8. Epilepsy/ or epilepsy.mp.
9. epilep$.mp.
10. seiz$.mp.
11. convuls$.mp.
12. 8 or 9 or 10 or 11
13. 7 and 12

Search Strategy for Older versus Newer Antiepileptic Drug Evaluation for MEDLINE, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews (each in OVID starting in 1950), Web of Science (limited to meeting abstracts only)

1. randomized controlled trial.pt.
2. controlled clinical trial.pt.
3. randomized.ab.
4. placebo.ab.
5. drug therapy.fs.
6. randomly.ab.
7. trial.ab.
8. groups.ab.
9. or/1-8
10. exp animals/ not humans.sh.
11. 9 not 10
12. epidemiologic studies/
13. exp case control studies/
14. exp cohort studies/
15. case control.tw.
16. (cohort adj (study or studies)).tw.
17. cohort.analy$.tw.
18. (follow up adj (study or studies)).tw.
19. longitudinal.tw.
20. retrospective.tw.
21. cross sectional.tw.
22. cross-sectional studies/
23. or/12-23
24. 11 or 24
25. Epilepsy/ or epilepsy.mp.
26. epilep$.mp.
27. seiz$.mp.
28. convuls$.mp.
29. 26 or 27 or 28 or 29
30. felbamate.mp.
31. gabapentin.mp.
32. lacosamide.mp.
33. lamotrigine.mp.
34. levetiracetam.mp.
35. oxcarbazepine.mp.
36. pregabalin.mp.
37. rufinamide.mp.
38. tiagabine.mp.
39. topriamate.mp.
40. vigabatrin.mp.
41. zonisamide.mp.
42. 31 or 32 or 33 or 34 or 35 of 36 or 37 of 38 or 39 or 40 or 41 or 42
43. 30 and 43
44. 44 and (11 or 24)