# Appendixes

Appendix A Search Strategies

Appendix B Data Extraction Forms

Appendix C Excluded Studies From Full-Text Review

Appendix D Glossary

Appendix E Abbreviations

Appendix F Baseline Characteristics for Included Studies and Trials

Appendix G Additional Evidence Tables

Appendix H Strength of Evidence for Outcomes

Appendix I Applicability of Indivual Studies and the Body of Evidence

Appendix J Forest Plots of Meta-analysis of Efficacy and Safety Endpoints